# Executive Summary

## I Introduction

As part of U.S. Department of Health and Human Services efforts to combat COVID-19 and prioritize health equity, the Office of the Assistant Secretary for Planning and Evaluation (ASPE) and the Office of the Assistant Secretary for Health (OASH) have sponsored a mixed-methods study of testing and vaccination policies and programs for people who are medically or socially at disproportionate risk for COVID-19 or related adverse outcomes (Best Practices for COVID-19 Testing and Vaccination Study). Study goals include identifying and examining promising and best practices to improve (1) COVID-19 testing awareness, access, and uptake; (2) COVID-19 vaccination confidence, access, and uptake; and (3) routine vaccination confidence, access, and uptake during the COVID-19 pandemic. Mathematica is ASPE’s research partner for the Best Practices for COVID-19 Testing and Vaccination Study, which started in 2022 and will finish in 2025.

Although the COVID-19 Public Health Emergency ended on May 11, 2023, the COVID-19 virus continues to cause illness, hospitalization, death, and disability. Moreover, experts agree that another pandemic is possible, and even likely. Findings from this study can support ongoing efforts to combat COVID-19 as well as efforts to prepare for future pandemics.

Purpose of this report. This report summarizes findings from an environmental scan of testing and vaccination policies and programs serving the populations of focus for the study, which we have defined as those who are medically or socially at disproportionate risk for COVID-19 or related adverse outcomes.^1^ This definition encompasses groups with medical conditions that increase their risk of infection and adverse outcomes, groups that face greater risk of COVID-19 exposure because of where they live and work, and groups facing barriers to services, such as restrictive work schedules, low transportation access, language barriers, or low levels of income. These findings will inform the design of other study components, including a national survey of local organizations that have implemented testing and vaccination programs and site visits to selected organizations. The study team will disseminate synthesized findings from all phases of the research to federal, state, tribal, and local practitioners and policymakers seeking to improve COVID-19 outcomes and prepare for future public health crises.

Methods and limitations. We developed search terms and a screening process for a targeted literature review of materials published since 2020. ^2^ We also interviewed key informants to identify guidelines and programs focusing on COVID-19 testing and COVID-19 vaccination and guidelines and programs focusing on routine vaccinations during the pandemic. We extracted information on programs from articles, websites, and our interview notes in an Excel-based tool. We analyzed this information using thematic inductive coding to identify themes within a taxonomy of program elements, including in program approaches, delivery strategies, implementation barriers, and implementation strategies. Because of the study’s timeline, we made choices that may have implications for our findings. First, we purposely limited the search of routine vaccination programs to those focused on halting the declining rates during the COVID-19 pandemic. Second, we limited the search to materials printed in English, although there is inherent selection bias in doing so. Another limitation is that relatively few literature sources discussed barriers to program implementation, although understanding this was a goal of the environmental scan.

## II Highlights of environmental scan findings^3^

### Populations at disproportionate risk of COVID-19 or related adverse outcomes and common barriers to testing and vaccination

Populations at disproportionate risk. People and communities may experience disproportionate risks of COVID-19 or related adverse outcomes due to medical factors, social factors, or both. People who are immunocompromised face higher risks of contracting COVID-19 and those with chronic conditions have increased risk of adverse outcomes from infection. Social factors such as living conditions or barriers to care can increase both the risk of COVID-19 exposure and adverse outcomes. These factors often intersect and compound to amplify risk. For example, structural inequities affecting some racial and ethnic groups have resulted in over-representation in essential service jobs and higher risk of COVID-19 exposure, high rates of medical conditions that increase risk of adverse COVID-19 outcomes, and low access to medical care. Populations that face disproportionate risks (medical, social, or both) include older adults and people with chronic conditions; Black, Hispanic or Latinx people, American Indian/Alaska Native people, and Native Hawaiian or other Pacific Islander people; people who live in rural areas; people who are incarcerated, experiencing homelessness, or residing in long-term care facilities; and people with disabilities, people with low income, and people who are uninsured.

Barriers to COVID-19 testing, COVID-19 vaccination, and routine vaccination. Populations at disproportionate risk of COVID-19 face multiple barriers to testing and vaccination related to awareness, confidence, and access. These barriers are rooted in historical and ongoing structural racism, economic inequality, and the inequitable allocation of social and health care resources.

- Awareness and confidence barriers include misinformation, low health literacy, digital divides, and language barriers (for example, lack of access to a computer or smartphone prevents people from being able to register online for testing or vaccination appointments) and distrust in the health care system, often rooted in a legacy of exploitation in clinical research and lived experiences of discrimination in health care settings.
- Access barriers include geographic barriers, such as for rural and farmworker communities where health care services are not readily available; transportation barriers and restrictive employment conditions that preclude some people from being able to reach testing and vaccination services or to take time off work to do so; and financial, health care, and legal barriers, such as not being able to lose wages to attend an appointment, perceived costs of vaccine or testing, not having a government-issued identification card, or fear of deportation, among others.
- Pandemic-related disruptions—such as stay-at-home orders, social and economic effects on families, and delays in receipt of many routine health care services, among others—exacerbated other barriers, leading to missed or delayed routine vaccinations.

Strategies to overcome barriers to testing and vaccination. Programs worked to help populations at disproportionate risk overcome barriers to awareness of, confidence in, and access to testing and vaccination. This report organizes findings on the programs we identified in the environmental scan using a taxonomy of program elements that includes approaches (the primary mechanism or vehicle programs used to achieve intended outcomes) and strategies for delivering those approaches (the activities used to make the program approach effective). We organize findings on approaches and strategies according to their goals (whether they sought to improve awareness, confidence, access, uptake, or a combination). In practice, most program approaches and strategies were designed to help people overcome barriers to one or more goals.

### COVID-19 testing programs

COVID-19 testing programs identified through the scan included primary approaches focused on increasing access. These included mass clinics or events, testing in health care settings, community testing clinics, mobile testing clinics, and in-home testing. Programs adopted a wide variety of strategies to enhance the effectiveness of these approaches.

- To increase awareness of, confidence in, and access to COVID-19 testing, programs often partnered with community organizations and trusted community leaders (such as faith leaders or school staff) or engaged multilingual staff to reduce barriers for those who did not speak English.
- Programs also worked to increase testing awareness and confidence by using multiple communication methods, such as using print materials, radio and TV ads, social media ads, and text messaging; sometimes tailoring or translating messages into other languages to raise awareness among specific populations. The programs prioritized comfort, safety, and dignity by doing things like erecting privacy screens and allowing people to collect their own samples.
- To increase access to testing, programs offered expanded hours and offered walk-up options, rather than limiting testing to those who made an appointment in advance. They also addressed financial barriers, reduced documentation requirements, and enhanced registration and tracking for those without internet access and those with low digital literacy. Some programs paired testing with other services, such as offering other health care services or providing concrete supports to address health-related social needs, like a hotel or food voucher.

Testing programs experienced resource limitations, logistical issues, and challenges with some partnerships. To address these challenges, programs maximized scarce resources by using volunteers or accepting donations from the government and partners, or by using the infrastructure of community partners, such as electricity, computers, and waiting areas. They also implemented logistical efficiencies to ease traffic and patient flow and used communication tools to streamline information sharing.

### COVID-19 vaccination programs

Some COVID-19 vaccination program approaches identified through the scan mirrored testing program approaches focused on improving access, including mass clinics or events, vaccination in health care settings, community vaccination clinics, mobile vaccination clinics, and even in-home vaccination for homebound populations. Other COVID-19 vaccination programs focused on increasing awareness and confidence via education events and outreach rather than vaccine delivery. Like testing programs, COVID-19 vaccination programs used a range of strategies to enhance the effectiveness of their primary approaches.

- COVID-19 vaccination programs partnered with trusted community groups, used multilingual staff, and coordinated with routine vaccination efforts to expand access for specific populations and to increase confidence in the new vaccines.
- Programs also developed culturally appropriate, translated messages; and used multiple dissemination channels to expand the reach of their messages.
- Programs expanded access to the vaccines by offering extended hours or walk-in appointments to get vaccinated, while some provided COVID-19 vaccinations without documentation requirements like identification, insurance, or proof of residency. Others helped with transportation services.
- A few programs offered financial incentives to increase uptake of COVID-19 vaccinations and others paired vaccinations with other services, such as offering contact tracing and COVID-19 testing, other health care services, or food assistance.

Common implementation challenges for vaccination programs were limited resources, including funding, staffing to meet demand, vaccine supply, and storage capacity (like ultracold freezers); information systems that could not exchange data with state or county systems about who was or was not vaccinated; and logistical challenges, such as transporting vaccines in rural communities or lack of wireless connectivity. In addition to using strategies adopted as part of COVID-19 testing efforts (like using volunteers), technical assistance helped many groups by educating staff and volunteers on topics like how to address vaccine hesitancy as well as by connecting programs with community partners. Flexible funding and vaccine donations helped to alleviate some resource constraints. A few programs conducted ongoing monitoring and quality improvement activities, such as collecting data to monitor vaccine equity and using the data to develop proactive strategies to reach underserved groups.

### Routine vaccination programs

The environmental scan found few programs focused on increasing routine vaccinations during the pandemic, although there is evidence that declining rates of routine vaccinations motivated some COVID-19 vaccination programs to focus on increasing routine vaccination uptake. Routine vaccination programs used similar approaches to COVID-19 testing and vaccination programs, including vaccination in health care settings, community and mobile vaccination clinics, and vaccine education outreach. Strategies to enhance the effectiveness of routine vaccination programs included drawing on COVID-19 vaccination strategies, at times bundling routine vaccines with COVID-19 vaccines, engaging multilingual staff, forming community partnerships, using multiple channels to amplify messaging, and coordinating with other health services.

Few routine vaccination programs reported implementation challenges, but some noted challenges bundling routine and COVID-19 vaccinations since routine vaccinations had different funding sources and thus required payment or insurance. Others noted staffing challenges, in some cases because staff were deployed to work on COVID-19 vaccination efforts or were overwhelmed by the pandemic. Some programs invested resources in training on specific vaccines and best practices for vaccine delivery, and others implemented quality improvement and evaluation efforts or invested in data infrastructure, which programs expect will have long-term benefits for routine vaccination delivery.

### Programs' approaches to identifying populations and assessing effectiveness

Programs in this review used published research and quantitative and qualitative data, sometimes in combination, to identify populations of focus and tailor their services to communities in need. For example, published literature and national COVID-19 surveillance reporting helped programs describe COVID-19 inequities by race, ethnicity, age, or other social factors and motivate or emphasize the importance of serving specific populations. Local surveillance data helped programs determine intervention sites in communities facing greater levels of transmission, hospitalization, and death from COVID-19; similarly, information on social vulnerability in specific neighborhoods helped them allocate resources. Programs also used data on COVID-19 testing and vaccination rates to identify communities in need of more services. Qualitative sources included surveys with community members, physician referrals, community working groups, and social media, all of which helped programs illuminate contextual and community-specific needs that might be missed using quantitative data.

Testing and vaccination programs that assessed their effectiveness used measures of the quantity and quality of their activities and services (program outputs). These measures included the reach of outreach and education efforts, number of clinics and events, number of appointments made or tests or vaccines ordered, number of tests or vaccine doses administered, number of people tested or vaccinated, geographic reach of services, and patient satisfaction. Less commonly, programs assessed outcomes, or measures of changes among program participants, such as changes in rates of COVID-19 testing and vaccination, changes in knowledge or attitudes about vaccination, and changes in routine vaccination rates, sometimes in relation to pre-pandemic rates.

## III Discussion

This environmental scan encompasses programs and policies focused on a variety of populations, operating at the local, state, and federal levels. Most other review or synthesis papers focus on only a single population group, or on either testing or vaccination. The breadth of our focus enables us to identify patterns in barriers to testing and vaccination services and cross-cutting themes in programs’ approaches and strategies. These themes support a taxonomy of program activities that aids understanding of how programs work to overcome various barriers to testing and vaccination. The breadth of our focus also supports informed recommendations for future research.

Our findings suggest that many barriers—and programs’ efforts to overcome them—are not unique to testing or vaccination, nor even to COVID-19. This is not surprising given that many barriers are rooted in historic and structural inequities. However, COVID-19 added complexity to existing barriers. For example, policies such as stay-at-home orders and early limits on vaccine eligibility inhibited both testing and vaccination for populations bearing the brunt of longstanding social inequities. Fears of missing work and losing income with positive test results inhibited testing for people with low-wage jobs.

Efforts to bring services closer to people were common across programs, as were partnership strategies and strategies for increasing trust. Many of the strategies leveraged community assets, such as partnerships, trusted leaders, systems and infrastructure. Although these strategies are used in other public health interventions, the COVID-19 pandemic also drove some innovations, such as a broader range of partnerships and financial and other supports for people testing positive.

The programs in this review helped people navigate barriers but did not address their root causes. For example, offering extended hours does not address the labor conditions that prevent essential workers from taking time off to get a test or vaccine. However, fixing structural issues is out of the scope and reach of most testing and vaccination programs. Federal policies, though, such as the free testing and vaccination and stimulus payments authorized by the CARES Act, could help to ameliorate structural inequities if they were extended and expanded.

Most programs in our review assessed their performance using outputs, or measures of the quantity and quality of their services, rather than outcomes or community feedback. Focusing on outputs alone, such as the number of people programs reach or the number of services they deliver, might not reveal the effectiveness of program approaches. However, a few programs used comparative outcome data, such as testing rates resulting from different program approaches, vaccination status compared to a baseline or control group, or vaccination and testing rates for different demographic groups. Other than a few programs that used satisfaction surveys, programs we reviewed did not report efforts to solicit community feedback. How communities perceive testing and vaccination programs should matter a great deal for any efforts to serve communities that are medically or socially at disproportionate risk of COVID-19 or related adverse outcomes.

## IV Implications for study design

The goal of this ASPE/OASH project is to disseminate findings on promising practices for closing gaps in COVID-19 testing and vaccination and routine vaccinations and for reducing inequities in testing and vaccination in future pandemics. Ultimately, learnings from this project might help inform policymakers’ efforts to mitigate the human and societal devastation of large-scale infectious disease outbreaks and the disproportionate impacts on those most at risk.

This environmental scan is only a first step in developing findings that will be useful to the field and to funders. Our findings point to the need for additional research on several topics, including how federal, state, and tribal context matter for programs, implementation challenges and strategies, which strategies programs view as effective, and how programs gauge community views of what works well, if at all. The project team will use this environmental scan’s findings and unanswered questions to shape a national survey of local organizations and site visits to states and tribal organizations, and the programs working within them. Guided by an expert panel of federal and nonfederal experts in COVID-19 testing and vaccination, the project will use these data sources and a theoretical framework to identify promising practices for reducing testing and vaccine inequities that will maximize learnings from the COVID-19 pandemic and response.

## V Implications for future pandemics and public health crises

The findings in this report focus on approaches and strategies to help people overcome barriers to COVID-19 testing, COVID-19 vaccination, and routine vaccination, but the findings are broadly applicable to future pandemics and public health emergencies. In fact, many findings in this report are also relevant to routine care and efforts to overcome persistent inequities in health and wellbeing. Most barriers to COVID-19 testing and vaccination and routine vaccination predated the pandemic, resulting from longstanding inequities in social conditions that drive observable differences in access and health service use. However, the COVID-19 pandemic added complexity to these barriers and to efforts to overcome them; the same will likely be true of future pandemics. Policymakers and practitioners at federal, state, tribal, and local levels should therefore consider how strategies identified in this report, such as working with trusted community partners to bring health services directly to places where people already congregate, can help to advance health equity in the near term. The findings in this report also suggest that policymakers and practitioners can prepare for future public health threats on two fronts: both by strengthening underlying community infrastructure, partnerships, and resilience, and by developing strategies and funding mechanisms specifically focused on overcoming barriers to public health services that might be exacerbated in a crisis.

1 Throughout this report, we refer to these groups as “populations at disproportionate risk.”

2 For further information on our methodology, see Appendix A.

3 Citations excluded from executive summary for brevity; see main body of report for all sources.