# VII Discussion

This environmental scan report has several strengths relative to the substantial literature on policies and programs intended to reduce remaining COVID-19 testing and vaccination disparities. Many published studies, including review or synthesis papers, focus on a single population group. Our literature search included programs focused on all populations that are medically or socially at disproportionate risk of COVID-19 or related adverse outcomes. We also reviewed programs implemented at the local, state, and federal level, focused on a range of outcomes for COVID-19 testing and vaccination and routine vaccination. In addition, we synthesized findings from peer-reviewed and gray literature and key informant interviews, which helps us mitigate publication bias and develop more holistic findings than other studies.

Because of the breadth of our focus and methods, we can identify patterns in barriers to services and cross-cutting themes in programs’ approaches and strategies. Our analysis revealed that many barriers—and programs’ efforts to help people overcome them—are not unique to testing or vaccination. These themes enabled us to create a taxonomy of program activities that aids understanding of what programs did and why. For example, both testing and vaccination programs sought to overcome access barriers by bringing services closer to people, and commonly worked with trusted messengers and community leaders to increase confidence in services. This taxonomy is based on sources we reviewed and is thus a work in progress; we expect to refine it in future phases of the project. Preliminarily, themes based on the sources we reviewed point to where information on promising practices might be most broadly useful. They also serve as a foundation for identifying less common and novel strategies, in both the sources we reviewed and in future research.

In the following discussion, we highlight themes in barriers to services and the strategies programs used to address resulting needs (Section VII.A). Next, we comment on programs’ implementation experiences and attempts to assess their performance (Section VII.B). Finally, the breadth of this environmental scan makes it possible to point to gaps in the literature. We close with a discussion of opportunities for further research, including for the survey and site visits planned as part of this study (Section VII.C).

## A Key findings across testing and vaccination programs

The COVID-19 testing and vaccination programs and routine vaccination programs that we reviewed worked to address similar barriers to service use. It is not surprising that programs with different foci addressed barriers such as lack of primary care access, lack of transportation, low income, and misinformation, given that these barriers are rooted in historic and structural inequities. For example, transportation barriers reflect economic inequality and maldistribution of public and private transportation resources. Misinformation is exacerbated by distrust of medical and public health systems among minoritized populations.

Some barriers were more common in the literature than expected: although distrust and low confidence are well known barriers to vaccination, they also posed barriers to COVID-19 testing. Distrust of medical and public health systems affected willingness to engage in testing as well as vaccination, necessitating trauma-informed approaches to service delivery (Neely et al. 2021). This finding is underscored by multiple delivery strategies that testing programs used to increase trust, such as working with community partners, using trusted community messengers, and prioritizing patient dignity.

Most barriers to COVID-19 testing and vaccination and routine vaccination predated the pandemic, although the pandemic added complexity. Inequities in social conditions are longstanding and continue to drive observable differences in access and service use across multiple systems, including health care. But some access and other barriers arguably rose to a higher level of complexity during the COVID-19 pandemic. Supply chain disruptions and pandemic-related policies such as stay-at-home orders and early limits on vaccination eligibility inhibited both testing and vaccination for the same populations bearing the brunt of longstanding social inequities. Although there were many similar barriers across program foci, the scan revealed several barriers unique to testing. Fear of missing work for a positive test result was a new barrier that emerged with the pandemic, and was more significant for people with low-wage jobs. In addition, lack of Internet access may have posed a relatively severe barrier to testing, compounding other barriers, since internet access is generally required not only to make an appointment but also to check one’s results.

Barriers to service use cluster and compound each other, resulting in multiple needs that are difficult for a single organization to address and helping to explain the prevalence of partnership strategies. As noted, social factors such as residential segregation, the inequitable allocation of social and health resources, concentrated poverty, over-representation in low-wage jobs and in the prison systems, and higher levels of chronic stress cluster together to create higher barriers to wellness for Black, Latinx, Indigenous, and other communities of color (Egede and Walker 2020; Pirtle 2020). This results in complex and multi-level needs among specific communities. Our finding that partnerships were common across programs we reviewed might reflect that partnerships are better suited than single organizations to address multiple needs. Although partnerships are a common strategy in other public health interventions, the COVID-19 pandemic seems to have expanded the range of partners working together. For example, the National Guard partnered with community organizations, although several programs noted that the National Guard’s presence caused fear in some communities.

Programs with all three study foci—COVID-19 testing and vaccination and routine vaccination—developed similar approaches, or primary mechanisms, for service delivery to enhance access. Programs sought to reduce travel burden on program recipients and to make services as convenient as possible. The most common approaches to delivering services were community clinics, followed by mobile clinics. COVID-19 vaccination and routine vaccination programs also commonly used stand-alone educational outreach approaches (without an accompanying service delivery component), although this approach was not used by testing programs in our review.

Likewise, programs used similar delivery strategies to enhance the effectiveness of their primary approaches and achieve desired outcomes. These strategies were frequently asset-based, leveraging existing community resources and relationships to meet multiple program goals. The most common delivery strategies across all programs were forming partnerships with community organizations and trusted leaders, using multiple channels to increase the reach of messaging, and developing population-specific or culturally tailored messaging. Many programs also engaged multi-lingual staff and coordinated with other health care services. We also found some strategies unique to testing or vaccination programs among the programs we reviewed. Offering financial and other supports (such as food and hotel vouchers) for people testing positive was a strategy unique to COVID-19 testing programs. Offering financial incentives to get vaccinated was a strategy unique to COVID-19 vaccination programs in the programs we reviewed.

Routine vaccination programs drew on resources and strategies used for COVID-19 vaccinations to close gaps in routine vaccinations. However, only a few COVID-19 vaccination programs in the literature we reviewed coordinated their efforts with routine vaccination efforts. As COVID-19 vaccines become more routinized, bundling them with routine vaccinations may become a more prevalent strategy. However, given both low COVID-19 vaccination uptake among some population groups and declining rates of routine vaccinations, effective strategies might also need to take advantage of opportunities to bundle vaccines with other health or social services, not related to vaccination.

The programs in this review helped people navigate barriers but did not address their root causes. For example, offering extended hours does not address the labor conditions that prevent essential workers from taking time off to get a test or vaccine. Providing services in convenient locations helps people without access to transportation but does not address the inequitable distribution of wealth and resources that results in differential car ownership or residence in areas without public transportation. However, fixing structural issues is out of the scope and reach of testing and vaccination programs.

The approaches and strategies programs used to help people overcome barriers to COVID-19 services are likely to be relevant in the next public health crisis. Without additional structural interventions, the next pandemic is likely to result in similar inequities in testing and vaccination rates. Programs may find themselves using many of the same approaches and strategies they developed during the COVID-19 pandemic in future pandemics or public health crises. To lessen the burden on programs to help people overcome barriers in times of crisis, federal policies, such as the free testing and vaccination and stimulus payments authorized by the CARES Act, could help to ameliorate structural inequities if they were extended and expanded.

## B Understanding programs' implementation experiences and performance

Testing and vaccination programs experienced similar implementation challenges, including resource limitations and logistical challenges. However, most of the sources we reviewed did not describe implementation challenges and strategies. Budget and funding constraints, limited staff, and shortages of tests and vaccines all posed barriers to programs’ effectiveness, in addition to supplies of equipment like freezers. Logistical challenges varied somewhat by program focus, although patient tracking and information sharing were cited by both testing and vaccination programs. Programs worked to develop creative solutions to these challenges, making use of volunteers, donated supplies, partners’ infrastructure, technical assistance, funding flexibilities, and other implementation strategies.

Programs commonly tracked outputs using data they collected as a part of their operations, such as the number of events they held and the number of tests and vaccines they administered. Relatively few programs assessed outcomes, such as changes in vaccine awareness, knowledge, or confidence among program participants or increased rates of testing and vaccination uptake at the community or population level. Outputs are helpful in specific ways. For example, they help programs quantify their reach and provide funders with information on how many people they were able to serve from different communities. Programs can also use outputs to understand how they can adjust implementation to reach more or different people, especially if they pair outputs with qualitative information on implementation experience or with community feedback. We did not see specific examples of programs conducting this kind of holistic implementation evaluation in the literature we reviewed, likely because they did not have the capacity or funding to do that work.

Focusing on outputs alone, such as the number of people programs reach or the number of services they deliver, might not reveal the effectiveness of program approaches. For example, outputs might not reveal whether program approaches ultimately worked to reduce testing or vaccine disparities, how many people programs need to reach to make a difference in testing or vaccination rates for certain groups, or how well or how quickly certain approaches worked compared to alternatives. Ideally, to gain a full understanding of their effectiveness, programs would synthesize outputs and outcomes and seek to learn about the relationships between them. Doing so helps programs understand the connections between program design, implementation choices, and outcomes. This would increase learnings available to programs and the field more broadly but would require additional capacity and funding.

Outcomes that incorporate comparative information put programs on a better footing to understand their effectiveness and share practices that advance the field. Several sources in our review were able to use comparative outcome data, such as testing rates resulting from different program approaches, vaccination status compared to a baseline or control group, or vaccination and testing rates for different demographic groups. Other metrics that could help programs put their work in perspective include community test positivity, speed of vaccine coverage in a community, and maintenance of high routine vaccination rates for specific communities, all compared to baseline measures.

Other than a few programs that used satisfaction surveys, programs we reviewed did not report efforts to solicit community feedback. How communities perceive testing and vaccination programs should matter a great deal for any efforts to serve communities at disproportionate risk. There is evidence to suggest that engaging communities to design COVID-19 testing and vaccination approaches is more effective than top-down approaches (Gilmore et al. 2020; Bogdewic and Ramaswamy 2021). Likewise, engaging communities to request feedback and to help define effectiveness—that is, what works for them—might help programs define promising and best practices in community-specific ways (Center for Evaluation Innovation 2017).

## C How these findings inform the survey and site visits for the study

This ASPE/OASH project is intended to develop and disseminate findings on promising and best practices for closing gaps in COVID-19 testing and vaccination and routine vaccinations and for reducing inequities in testing and vaccination in future pandemics. Ultimately, these practices could help to reduce the human and societal devastation of large-scale infectious disease outbreaks and the disproportionate impacts on those most at risk.

To achieve these goals, best practices must meet the needs of the communities they seek to serve and be feasible, replicable, and sustainable. They should help future programs select approaches and decide how to deliver and implement them, including how to overcome likely implementation challenges. They should also influence how federal and state agencies and private funders support local programs—for example, findings of this report suggest that flexibility in funding guidelines will help local programs adapt to changing conditions.

This environmental scan is only a first step in developing findings that will be useful to the field and to funders. Our findings point to the need for further research on the following topics.

- Context and how it interacts with programs. Future research could shed light on how federal, state, or tribal policy contexts intersect and matter for programs, and on best practices for programs working in specific contexts. New research could also focus on how programs have evolved, shifted, and adapted as context changes, and on how community characteristics such as resilience can improve service delivery.
- Information programs need to make choices. Most sources we reviewed for this environmental scan did not report implementation challenges or strategies for overcoming them. Programs need additional information on these topics to make design and implementation choices. Future research could also shed light on the kinds of information programs need to understand how to align programmatic options with community needs.
- Effectiveness. This report illuminates patterns in programs’ approaches and strategies but cannot determine which are most effective, and the available information on outcomes is limited. More research is needed on the approaches and strategies that programs view as effective, and how they assess this. More importantly, future research should assess community views of what works well, and how programs take community views into account, if at all.

The project team will use the findings and unanswered questions from this environmental scan to shape a national survey of local organizations and site visits to states and tribal organizations. Guided by an expert panel of federal and nonfederal experts in COVID-19 testing and vaccination, the project will use these data sources and a theoretical framework to identify and disseminate best practices for reducing testing and vaccine inequities that support the efforts of local, state, tribal, and national organizations and public agencies at all levels. Synthesized findings from the environmental scan, national surveys, and site visits can help to inform efforts to strengthen capacity and preparedness for the next pandemic or public health crisis, as well as efforts to advance equity in health care, health, and wellbeing in the meantime.