# VI Programs' approaches to identifying populations and assessing performance

This section provides details on the data sources the programs in our review used to identify priority populations and the metrics they used to assess their performance. We first discuss programs’ approaches to identifying populations of focus and then describe how they assessed their activities and success.

## A Data sources to identify populations at disproportionate risk

In Section II, we described populations that are medically or socially at disproportionate risk of COVID-19 and related adverse outcomes and the populations of focus for the programs we reviewed. In this section, we describe the data sources programs used to identify populations of focus—according to individual risk factors—or areas in need of services (summarized in Exhibit VI.1). Most of these data sources characterize geographic areas rather than people or groups.

Exhibit VI.1 Data sources used to identify populations at disproportionate risk and direct services

Type | Example Sources | Example Metrics | Advantages | Limitations
National COVID-19 epidemiology data and data about attitudes about COVID-19 vaccines | - Peer-reviewed literature; - Federal reporting, for example from the CDC Morbidity and Mortality Weekly Reports (https://www.cdc.gov/mmwr/index.html); - National COVID-19 surveillance data from the CDC COVID Data Tracker (https://covid.cdc.gov/covid-data-tracker/#datatracker-home), sometimes disaggregated by race and ethnicity (https://covid.cdc.gov/covid-data-tracker/#demographics); - National surveys assessing attitudes about COVID-19 vaccination, for example, from the Pew Research Center (https://www.pewresearch.org/) | - National rates of COVID-19 incidence, test positivity, hospitalizations, and deaths, disaggregated by race/ethnicity; - Self-reported willingness and intent to be vaccinated | - Provide broad overview of patterns and inequities in disease incidence, prevalence, burden, and public attitudes; - CDC data are updated regularly; - Reliable estimates from large national samples; allows for disaggregation by important subpopulations | - Data displayed at the national level do not reveal localized patterns and heterogeneities; - Missing race and ethnicity data masks disparities in COVID-19 incidence
Local COVID-19 epidemiology data | - City, county, or state public health department COVID-19 surveillance data; - County-level COVID-19 surveillance data from the CDC COVID Data Tracker (https://covid.cdc.gov/covid-data-tracker/#maps_new-admissions-rate-county) | - Neighborhood-level rates of COVID-19 incidence, test positivity, hospitalizations, and deaths, disaggregated by race/ethnicity | - Identify hotspots and heterogeneity in COVID-19 burden within cities, counties, and states; - Respond to real-time community needs (with ongoing monitoring) | - Limited testing availability in communities with low income and communities of color results in under-assessment of COVID-19 incidence; - Missing race and ethnicity data masks disparities in COVID-19 incidence; - Limited availability of reliable local data, especially disaggregated by race/ethnicity or other demographic characteristics
Local data on COVID-19 testing and vaccination | - Local information on availability of testing venues; - Vaccination rates from health care organizations, local public health departments, or county-level data from the CDC COVID Data Tracker (https://covid.cdc.gov/covid-data-tracker/#maps_new-admissions-rate-county), sometimes disaggregated by race and ethnicity | - Locations or numbers of neighborhoods that have few known testing venues; - Percent of residents vaccinated, disaggregated by race and ethnicity | Identify communities in need of more services | - Differences in reporting make it difficult to identify and prioritize communities of focus; - Limited availability of reliable local data, especially disaggregated by race/ethnicity or other demographic characteristics
Data on community characteristics | - CDC’s Social Vulnerability (https://www.atsdr.cdc.gov/placeandhealth/svi/index.html) Index (SVI); - COVID-19 Vulnerability Index, constructed using Medicare data; - Neighborhood racial and ethnic composition data from the U.S. Census or American Community Survey (https://www.census.gov/programs-surveys/acs) | - Census tract SVI score; - Percent of residents with different racial identities (for example, percent non-Hispanic Black) | - Places focus on “upstream” social and structural factors that shape multiple health inequities | - Geographic boundaries for census-based measures may not correspond to people’s neighborhood definitions; - SVI and racial/ethnic composition do not capture all barriers to testing and vaccination
Data from communities (often qualitative) | - Referrals from service providers; - Community working groups; - Surveys of participants or community members; - Social media; - Expert input | - Counts of people with greater risk of adverse outcomes, such as homebound adults; - Qualitative descriptions of a community’s barriers, needs, and opportunities; - Fears, misinformation, strengths expressed online | - Illuminates contextual or community-specific considerations that would be missed using other data sources; - Integrates community voice in data for decision making | - Qualitative research is sometimes perceived as less rigorous or valuable
Multiple data sources used in combination | - National and local; - Qualitative and quantitative | - Multiple | - Triangulating data sources provides a more accurate picture of community needs and assets | - Time- and resource-intensive

Note: Advantages and limitations of metrics and data sources are based on subject matter expertise of research team. Most sources we reviewed did not explicitly describe such advantages and limitations.

National COVID-19 epidemiology data, obtained from published literature and federal reporting helped programs describe COVID-19 transmission, burden, and inequities by individual risk factors, including race, ethnicity, age, or relevant social factors. Peer-reviewed and gray literature sources on COVID-19 testing and vaccination programs often cited other published information on disparities or needs among specific groups (Abdul-Mutakabbir et al. 2022; Chamie et al. 2022; Kepka et al. 2021). Many programs cited federal reporting from the CDC’s Morbidity and Mortality Weekly Report (MMWR) (Abdul-Mutakabbir et al. 2022, Feifer et al. 2021; Washington et al. 2022) and COVID Data Tracker (Abdul-Mutakabbir et al. 2021; Abdul-Mutakabbir et al. 2022; Alcendor et al. 2022), often disaggregated by race and ethnicity to describe racial inequities in COVID-19 incidence, morbidity, mortality, and vaccination rates (Mullin et al. 2022; Peteet et al. 2022). However, it was not always clear whether these programs used this information to identify populations of focus as they designed programs, or whether they used it to communicate specific populations’ (already well-known) need for services or the role of structural, social, and medical factors in driving COVID-19 inequities. Several programs also cited national surveys to describe attitudes about COVID-19 vaccination, including confidence or willingness to be vaccinated (Bigelow et al. 2022; Budhwani et al. 2023; Washington et al. 2022).

Local epidemiology data on COVID-19 transmission and burden helped programs develop place-based interventions. Surveillance data from city, county, and state health departments enabled programs to select service delivery sites in communities facing greater levels of transmission, hospitalization, and death from COVID-19 (Jaklevic et al. 2021; Kim et al. 2021; McCollum et al. 2022). For example, a COVID-19 testing program in Chicago used daily reports on the number of COVID-19 cases from the City of Chicago to identify specific neighborhoods with clusters of cases (Kim et al. 2021). Disaggregating COVID-19 data by race or other demographic factors enabled programs to identify inequities within cities or states and plan service sites accordingly (Brown et al. 2021; Chamie et al. 2022; DeGarmo et al. 2022; Kim et al. 2021). Other testing programs used local epidemiology data in conjunction with machine learning and mapping approaches to identify emerging hotspots of COVID-19 transmission (Atrium Health 2020; Whanger et al. 2022). For example, a mobile testing clinic in West Virginia used a machine learning algorithm to identify counties with predicted one-week increases in COVID-19 incidence based on local epidemiology and other data (Whanger et al. 2022).

Reviewing place-based data on COVID-19 testing and vaccination access and use helped programs identify specific communities in need of more testing and vaccination resources. Several COVID-19 testing programs selected communities with low testing availability (Hernandez et al. 2022; Whanger et al. 2022). For example, one program deployed mobile vans to communities with limited or no testing venues; however, authors did not state the data source used to determine testing availability (Whanger et al. 2022). Vaccination programs often focused their efforts in communities with low rates of vaccination using data from health care organizations (Beste et al. 2021; Bigelow et al. 2022), state health departments (Alcendor et al. 2021), or localized (rather than national) vaccination information from the COVID Data Tracker (Abdul-Mutakabbir et al. 2022); key informants echoed these approaches.

Programs used place-based data to prioritize communities identified as socially vulnerable without an explicit focus on COVID-19 transmission or burden. Social vulnerability stems from structural and social inequities and reflects community capacity to respond to stresses such as COVID-19 outbreaks (Tsai et al. 2022). Several programs identified communities of focus using data from the CDC Social Vulnerability Index (SVI), an area-based measure of community resilience often used for planning and allocating resources (Berkley-Patton et al. 2022; Massachusetts Department of Public Health 2021; Public Health—Seattle and King County 2021). Key informants also described using the SVI as a data source, including representatives of a CBO, a state health department, a foundation, and several federal agencies. One program constructed its own COVID-19 Vulnerability Index using Medicare data (Baker et al. 2021). Programs in our literature review that aimed to serve specific racial and ethnic groups also referenced data on neighborhood racial composition to determine service locations (Barrett et al. 2022; Dumproff et al. 2022; Gillwald et al. 2022; Singler et al. 2023) or used the American Community Survey to understand the demographics of communities they reached (Baker et al. 2021).

Other programs used qualitative data to identify specific people or populations and plan services, including data from physician referrals, community work groups, surveys, social media, and experts' knowledge of communities. Several programs used physician referrals to identify people at high risk of COVID-19 or severe outcomes, including veterans with multiple risk factors (Beste et al. 2021) and adults who were older, frail, or homebound (Goldberg et al. 2020). Programs also used community work groups to prioritize populations, understand contextual factors, and plan service delivery. For example, one program planned the site for their COVID-19 vaccination intervention based on expert input from a working group of local community partners (AuYoung et al. 2021). Based on their deep knowledge of the community, the working group was able to provide more nuanced information about intersectional factors affecting risk of COVID-19 exposure, including occupation and household composition for specific groups. As another example, a COVID-19 testing program in Northern California formed a Latino COVID-19 collaborative comprised of community partners, residents, and academics. To plan locations for COVID-19 testing events, the collaborative conducted a brief survey of community members to understand barriers to testing and met monthly to discuss findings and plan test sites accordingly (Chamie et al. 2022). Several key informants described similar approaches to identifying populations of focus based on historical knowledge of the communities they serve.

Key informant spotlight: Using social listening

Staff from a foundation working throughout the country and its funded community-based organizations followed social media conversations about COVID-19 testing and vaccination to identify emerging patterns of COVID-related fears, strengths, concerns, and misinformation. This so-called social listening approach enabled program staff to identify real-time topics of conversation predominant among specific communities and respond in contextually specific ways.

Synthesizing multiple data sources helped programs gain a robust understanding of community needs and assets and plan accordingly. Many of the programs we reviewed began with an overview of national epidemiologic data to describe inequities in the COVID-19 burden across social groups, then assessed more localized data or expert input to select communities of focus (Barry et al. 2020; Brown et al. Public Health - Seattle and King County 2021). Some programs combined population characteristics from several data sources to select program sites (Barrett et al. 2022; Whanger et al. 2022). For example, a multi-city mobile vaccination program run by the Puget Sound Veterans Affairs Health Care System developed a survey to assess veterans’ risk factors for severe COVID-19 outcomes, aggregated survey data at the zip code level, and combined survey data with place-based sociodemographic data to prioritize sites for mobile vaccination clinics (Beste et al. 2021). A vaccine equity team then assisted program planners in interpreting emerging trends and tailoring services accordingly. Key informants sometimes reported using multiple data sources as well. For example, one key informant representing an academic institution working statewide combined test positivity rates with geographic information to understand distance from testing centers in zip codes with high test-positivity rates.

Key informant spotlight: Combining the Social Vulnerability Index with qualitative input

A state health department mapped data from the Social Vulnerability Index at the zip code level. The health department then found trusted partners (local public health boards, tribal public health boards, federally qualified health centers, and community-based organizations) in those zip codes to collect data about level of need for vaccines, and then the state health department allocated vaccines accordingly.

## B Metrics programs reported using to assess performance

In this section, we describe the metrics and data sources programs used to assess their performance and understand the effects of their work. Programs in our review that mentioned specific metrics or data sources for this purpose typically assessed program outputs, which are measures of the quantity and quality of program activities and service delivery. Some programs also assessed program outcomes, which are measures of changes among program recipients, such as changes to COVID-19 testing and vaccination awareness and confidence and changes in testing and vaccination rates. Table VI.2 lists outputs and short-term outcomes used by programs in our review.

Exhibit VI.2 Metrics programs used to assess their effectiveness

Focus | Program outputs | Program outcomes
COVID-19 testing | - Measures of outreach; - Number of clinics and events; - Number of appointments made; - Number of tests ordered; - Number of tests administered; - Number of people tested; - Geographic reach of services; - Participant satisfaction | - Population rates of testing
COVID-19 vaccination | - Measures of outreach or education efforts; - Number of clinics and events; - Number of appointments made; - Number of vaccine doses administered; - Number of people vaccinated; - Geographic reach of services; - Participant satisfaction | - Changes in knowledge about vaccination and willingness or intent to be vaccinated (vaccine confidence); - Population rates of vaccination
Routine vaccination | | - Population rates of vaccination, sometimes in relation to pre-pandemic rates

Note: Metrics in this table reflect only those that were used by the programs we reviewed. There are other possible metrics that we did not see in this targeted review such as changes in knowledge about or confidence in COVID-19 testing, or COVID-19 vaccinations metrics that distinguish between any dose, first dose, series completion, or boosters. Many metrics could be assessed overall and by race, ethnicity, age, and other demographic characteristics.

### 1 Program outputs

Types of program outputs in our review were similar across COVID-19 testing, COVID-19 vaccination, and routine vaccination programs. Programs generally tracked outputs using data they collected as a part of their operations. They commonly disaggregated these outputs by demographic characteristics such as age and race.

Programs focused on outreach and education assessed their reach using a variety of measures, depending on the type of outreach or education activity. Examples include number of phone calls made (Deerin et al. 2022), text messages sent (Marquez et al. 2021a), doors knocked on (Relias Media 2022), radio advertisements aired (Long et al. 2021), and social media advertisements distributed (Singler et al. 2023). Some vaccine education campaigns tracked user engagement with and reactions to social media (Marcell et al. 2022; Singler et al. 2023). Programs also monitored the number of people attending educational events. For example, in one NIH-funded program, mental health therapists delivered a COVID-19 educational intervention to 254 clients from March to June 2021 (Venegas-Murillo et al. 2021).

Programs delivering testing and vaccination services typically counted services and people served to characterize their activities, although some assessed geographic reach or participant satisfaction.

- Number of clinic sites or number of events held. Programs tracked the number of sites established or used, including at mass sites, health care setting-based clinics, venue-based clinics, and mobile units, as well as the number of testing and vaccination events they held at these sites (Dumproff et al. 2022; Hernandez et al. 2021). For example, a FQHC-administered program delivering COVID-19 testing to people experiencing homelessness offered testing in 37 Health Care for the Homeless (HCH) clinics across the nation (Berner et al. 2022). Because their goal was to serve many people in one location, mass testing and vaccination clinics tended to have fewer sites; for example, one mass testing program hosted two drive-through and six walk-up testing sites in Chicago (Kim et al. 2021). Testing and vaccination programs that characterized their services as events reported the number of events held, usually over a specific time frame (Faherty et al. 2022; DeGarmo et al. 2022; Berner et al. 2022; Evans et al. 2021). For example, a program run by the Los Angeles County Health Department in partnership with the University of California, Los Angeles held over 157 vaccination events for people experiencing homelessness in Los Angeles, as of August 2021 (Choi et al. 2022).
- Number of home test kits ordered and vaccine appointments made. Several at-home testing programs tracked the number of test kits distributed (Barrett et al. 2022; Singler et al. 2023). Vaccination programs tracked the number of appointments made (Osibanjo et al. 2022).
- Number of tests and vaccines delivered and number of persons receiving tests or vaccination. The most common program outputs tracked by COVID-19 testing programs were the number of tests they administered and the number of people they tested. For example, a mass testing site in West Virginia administered 98,846 tests between May and December of 2020 (Dumproff et al. 2022). A walk-up testing site in New Orleans tested 9,721 individuals over a 50-day period (Hernandez et al. 2021). Likewise, COVID-19 and routine vaccination programs tracked the number of individuals vaccinated and the number of vaccine doses administered. For example, a routine vaccination program in Boston delivered 146 vaccinations to 50 children through mobile clinics (Leibowitz et al. 2021). Many programs reported the demographics of people receiving services (Baker et al. 2021; Bigelow et al. 2021; Davis et al. 2020; Feifer et al. 2021).
- Geographic reach of testing and vaccination services. Some programs described their geographic reach, including the number of counties they served (Baker et al. 2021; Brown et al. 2021; Dumproff et al. 2022) and distance traveled or census tract coverage among people receiving services (Chamie et al. 2022; Hernandez et al. 2021). Several sources in this review included maps to show programs’ geographic reach (Brown et al. 2021; Hernandez et al. 2021). Likewise, one key informant at a local health department described regularly updating a map of intervention sites to show where vaccination mobile units had been deployed to deliver vaccines.
- Participant satisfaction. Programs assessed participants’ satisfaction with testing and vaccination services to understand opportunities for improvement; this could be characterized as either an output or outcome. Several programs administered surveys to assess satisfaction with testing and vaccination services (Baker et al. 2021; Leibowitz et al. 2021; Marquez et al. 2021a; Sears et al. 2022; Whanger et al. 2022). For example, a mobile COVID-19 testing program asked families questions about the ease of scheduling appointments, convenience of the mobile vaccination unit, quality of care, and whether services were offered in a way that was easy to understand and met their cultural and language needs (Leibowitz et al. 2021). Despite the emphasis on community buy-in and engagement, few programs seemed to measure community satisfaction more broadly.

### 2 Program outcomes

Program outcomes are changes in program participants’ behavior, knowledge, skills, status (such as vaccination status), or level of functioning. Examples of short-term outcomes include changes in vaccine awareness, knowledge, or confidence and increased rates of testing and vaccination uptake at the community or population level. Long-term outcomes could include reduced COVID-19 transmission, morbidity, and mortality, although only one of the programs we reviewed assessed a long-term outcome (Hansotte et al. 2021).

Programs conducting vaccination outreach and education used surveys to measure changes in knowledge and attitudes. As a part of their evaluation efforts, several programs administered surveys to measure changes in program recipients' knowledge about vaccination and willingness to be vaccinated, before and after receiving the intervention (Sears et al. 2022; Venegas-Murillo et al. 2022). For example, a community-academic partnership that delivered a vaccine education webinar to Black churchgoers in the western U.S. documented a statistically significant increase in participants' willingness to be vaccinated after the webinar in comparison to before (Peteet et al. 2022). No testing programs in our review assessed changes in people's attitudes about testing, likely because we did not identify testing programs focused on education or outreach without a testing delivery component. A few other testing and vaccination surveyed knowledge and attitudes at a single point in time, but they did so to understand barriers to services rather than program effectiveness (Chamie et al. 2022; Long et al. 2021).

Program spotlight: Increasing vaccination knowledge and self-efficacy among tribal communities in Arizona

A partnership between the University of Arizona and three tribal communities implemented a COVID-19 vaccination education campaign to increase vaccine knowledge and self-efficacy among tribal community members through outreach from trusted community members and culturally tailored printed materials. Comparisons of pre-test and post-test survey results indicated statistically significant changes in knowledge about how the COVID-19 vaccine works, possible side effects, and how to schedule vaccine appointments (Sears et al. 2022).

Program spotlight: Increasing testing among Latinx communities through culturally tailored promotion and outreach

The Oregon Saludable: Juntos Podemos (Healthy Oregon: Together We Can) program randomized communities to receive culturally tailored COVID-19 testing information, designed to increase trust and delivered by promotoras, versus outreach as usual. By comparing population-level rates of testing among Latinx people in treatment versus control counties, authors were able to show that the program increased testing among the Latinx community (Degarmo et al. 2022).

Some assessed changes in rates of testing and vaccination at the community level. For example, several vaccination programs assessed vaccination rates using immunization registries or other surveillance data (Osibanjo et al. 2022; Marquez et al. 2021a; Public Health—Seattle and King County 2021). One routine vaccination program reported trends in children’s seven-vaccine series relative to pre-pandemic trends, given the focus on addressing interruptions to routine vaccination schedules during COVID-19 (Deerin et al. 2022). Although less common than for the vaccination programs, several testing programs also measured community-level testing rates: one program compared rates between census tracts with walk-up versus drive-through testing options (Hernandez et al. 2022); another program compared changes over time in population testing rates between counties receiving different kinds of testing outreach strategies (DeGarmo et al. 2022).

Other programs, including both outreach and service delivery programs, quantified differences in testing and vaccination rates between people receiving specific interventions and a control group. For example, several programs designed randomized controlled trials to compare culturally tailored outreach strategies for testing and vaccination services to standard strategies (Barrett et al. 2022; Berkley-Patton et al. 2022; Budhwani et al. 2022; Degarmo et al. 2022). Similarly, a key informant’s academic institution compared outcomes for participants in testing events throughout the state to a control group. Outcomes of interest included adherence to recommended CDC guidelines, such as isolating when infection happened, masking, and vaccination status.

Testing and vaccination programs reported outcomes that were disaggregated by race, ethnicity, age, gender, and social factors (Beste et al. 2021; DeGarmo et al. 2022; Hansotte et al. 2021). This approach enabled programs to explicitly evaluate their impact on testing and vaccine inequities. For example, an article describing a community testing clinic, run by a county health department in partnership with CBOs, reported changes in countywide testing rates by race and ethnicity during the study period (Hansotte et al. 2021). Key informants from state and local health departments, as well as a national pharmacy retailer, likewise described using vaccine dashboards or other internal databases to assess vaccination data by race and ethnicity, or among certain groups such as people experiencing housing insecurity. A key informant from a federal agency also noted that its awardees were required to monitor vaccination coverage among demographic subgroups and communities with high social vulnerability (using the SVI).