# V Key findings on routine vaccination

This section provides an overview of guidelines for routine vaccinations and how the COVID-19 pandemic affected routine vaccination rates (Section V.A). We then summarize the routine vaccination programs’ primary approaches and delivery strategies, the implementation challenges they experienced, and the implementation strategies they used to overcome those barriers (Section V.B).

## A Routine vaccination guidelines, changes in vaccination rates during the COVID-19 pandemic, and pandemic-related barriers to routine vaccination

Guidelines for recommended routine vaccinations vary by age, as outlined in Exhibit V.1 below. In addition to age-specific guidelines, influenza vaccination is recommended yearly across age groups, starting at age 6 months (CDC 2016).

Exhibit V.1 Guidelines on routine vaccinations by age group as of April 2023

Age group | Recommended vaccination | Recommended schedule
Children under age 6 ^a^ | Hepatitis B (HepB) | Administered in three doses: at birth, ages 1–2 months, and between ages 6–18 months
Children under age 6 ^a^ | Rotavirus (RV) | Administered in two or three doses (depending on the vaccine brand): at ages 2 months, 4 months, and 6 months
Children under age 6 ^a^ | Diphtheria, pertussis, tetanus (DTaP) | Administered in five doses: at ages 2 months, 4 months, 6 months, between 15–18 months, and between 4–6 years
Children under age 6 ^a^ | Haemophilus influenzae type b (Hib) | Administered in three or four doses (depending on the vaccine brand): at ages 2 months, 4 months, 12 months, and at 6 months in the four-dose series
Children under age 6 ^a^ | Pneumococcal disease (PCV13, PCV15) | Administered in four doses: at ages 2 months, 4 months, 6 months, and between 12–15 months
Children under age 6 ^a^ | Polio (IPV) | Administered in four doses: at ages 2 months, 4 months, between 6–18 months, and between 4–6 years
Children under age 6 ^a^ | Measles, mumps, and rubella (MMR) | Administered in two doses: between ages 12–15 months and between ages 4–6 years
Children under age 6 ^a^ | Varicella (Chickenpox) | Administered in two doses: between ages 12–15 months old and between ages 4–6 years
Children under age 6 ^a^ | Hepatitis A (HepA) | Administered in two doses: at age 12 months and between ages 18–23 months
Children under age 6 ^a^ | Influenza | Recommended yearly after 6 months of age
Children under age 6 ^a^ | COVID-19 | The number of doses recommended vary by vaccine history, age, and type of COVID-19 vaccine ^e^
Youth between ages 9–17 ^b, c^ | Meningococcal conjugate vaccine (MenACWY) | Administered in two doses: at ages 11– 12 years and at age 16
Youth between ages 9–17 ^b, c^ | Human papillomavirus (HPV) | Administered in a two-dose series, separated by 6–12 months, starting as young as age 9
Youth between ages 9–17 ^b, c^ | Tetanus, diphtheria, pertussis, booster (Tdap) | Administered between ages 11–12 years
Youth between ages 9–17 ^b, c^ | Meningococcal vaccine for serogroup B virus (MenB) | Recommended for those at risk due to an outbreak and for people with specific medical conditions
Youth between ages 9–17 ^b, c^ | Influenza | Recommended yearly
Youth between ages 9–17 ^b, c^ | COVID-19 | The number of doses recommended vary by vaccine history, age, and type of COVID-19 vaccine ^e^
Adults ages 18 and over ^d^ | Hepatitis B (HepB) | Recommended for adults ages 19–59. Administered in two, three, or four doses (depending on the vaccine brand)
Adults ages 18 and over ^d^ | Tetanus (Td) or Tetanus, diphtheria, pertussis (Tdap) | Td or Tdap booster recommended every 10 years and one Tdap booster recommended during pregnancy
Adults ages 18 and over ^d^ | Measles, mumps, and rubella (MMR) | Recommended for adults if no evidence of immunity or prior vaccination is available
Adults ages 18 and over ^d^ | Varicella (Chickenpox) | Recommended for adults if no evidence of immunity or prior vaccination is available
Adults ages 18 and over ^d^ | Human papillomavirus (HPV) | Recommended for adults through age 26 years, if an initial HPV series was not completed using the recommended dosing intervals
Adults ages 18 and over ^d^ | Pneumococcal vaccines | Recommended for all adults ages 65 years and older and persons with certain medical conditions
Adults ages 18 and over ^d^ | Shingles (zoster) | Recommended for adults over age 50
Adults ages 18 and over ^d^ | Influenza | Recommended yearly
Adults ages 18 and over ^d^ | COVID-19 | The number of doses recommended vary by vaccine history and type of COVID-19 vaccine ^e^

Notes: The table outlines routine vaccination guidelines. CDC also provides detailed recommendations for catch-up vaccinations for children, for people with specific risk factors, and for people in geographic areas where diseases (such as dengue) are endemic. The following references provide additional information and comprehensive guidelines.

Sources:

a Centers for Disease Control and Prevention. (February 10, 2023). Recommended Vaccinations for Infants and Children, Parent-Friendly Version. Birth through 6 Years, United States, 2023. https://www.cdc.gov/vaccines/schedules/easy-to-read/child-easyread.html. Accessed May 2, 2023.

b Centers for Disease Control and Prevention. (October 12, 2021). Meningococcal Vaccine Recommendations. https://www.cdc.gov/vaccines/vpd/mening/hcp/recommendations.html. Accessed March 16, 2021.

c Centers for Disease Control and Prevention. (February 10, 2023). Recommended Vaccinations for Children 7 to 18 Years Old, Parent-Friendly Version. https://www.cdc.gov/vaccines/schedules/easy-to-read/adolescent-easyread.html. Accessed May 2, 2023.

d Centers for Disease Control and Prevention. (April 27, 2023). Adult Immunization Schedule by Age. https://www.cdc.gov/vaccines/schedules/hcp/imz/adult.html#note-pneumo. Accessed May 2, 2023.

e Centers for Disease Control and Prevention. (May 31, 2023). COVID-19 Vaccine Interim COVID-19 Immunization Schedule for Persons 6 Months of Age and Older. https://www.cdc.gov/vaccines/covid-19/downloads/COVID-19-immunization-schedule-ages-6months-older.pdf. Accessed June 1, 2023.

Routine vaccination rates for school-age children and youth fell during the COVID-19 pandemic but were relatively consistent for children in the first 24 months of life. Children who were living below the poverty level, uninsured or on Medicaid, or in rural areas experienced declines in vaccination rates. CDC data on children in kindergarten during the 2020–21 school year show a 1-percent decrease in vaccination rates across routine vaccinations (including the measles, mumps, and rubella vaccine; the diphtheria, pertussis, tetanus vaccine; and the varicella vaccine) compared to the 2019–20 school year (Seither et al. 2022). A similar 1-percent decrease occurred between the 2020–21 and 2021–22 school year (Seither et al. 2023). For younger children, born in 2018–2019, vaccination coverage remained consistent during the pandemic for most routine vaccinations (Hill et al. 2023). However, flu vaccination rates for children ages 6 months to 17 years dipped by 6 percentage points in the 2020–21 flu season compared to the 2019–20 season (Williams et al. 2022). There were also reductions in human papillomavirus (HPV) vaccination rates for youth, with one study estimating a 60 percent decline in March–May 2020 compared to March–May 2021 (Stokley 2022; Patel Murthy et al. 2021). Studies have also demonstrated disparities in vaccination coverage for specific populations during the pandemic. For example, despite overall consistency in vaccine coverage for children in the first 24 months of life, one study identified dips in routine vaccination for children under 24 months who were living in rural areas or below the federal poverty level (Hill et al. 2023). The study also noted persistent disparities in vaccination coverage by race and ethnicity and socioeconomic status, with routine vaccination coverage being lowest among Black children and children without private insurance (Hill et al. 2023). Another study similarly identified that children who were uninsured or insured through Medicaid had sharper declines in routine vaccination compared to the general population (Skolnik et al. 2021).

Influenza vaccination rates were associated with COVID-19 vaccination rates for adults ages 18–64. Flu vaccination rates for adults remained relatively consistent between the 2019–20 and 2020–21 flu seasons (Williams et al. 2022; Leuchter et al. 2022). However, this relationship shifted in 2021–22 after the introduction of COVID-19 vaccinations. To illustrate, in the 2021–22 flu season, states with the highest rates of COVID-19 vaccination experienced an increase in rates of flu vaccination compared to the 2019–20 flu season. States with the lowest rates of COVID-19 vaccination in 2021–22 experienced a decrease in flu vaccination rates compared to the 2019–20 flu season (Leuchter et al. 2022). This suggests that factors influencing rates of COVID-19 vaccination, such as mistrust, may have also impacted flu vaccination rates (Leuchter et al. 2022).

Pandemic-related disruptions in health care, fears about COVID-19 transmission, and social and economic impacts on families were primary causes of reduced rates of routine vaccinations. Studies suggest that reduced availability of primary care services during the pandemic, parental concerns about COVID-19 transmission, social and economic effects of the pandemic on families, stay-at-home orders, and disruption to the health care system contributed to declines in routine vaccination rates during the pandemic (Santoli et al. 2021; Stokley 2022; Seither et al. 2022). Programs in our review observed similar pandemic-related barriers to routine vaccinations. For example, one health center in Boston developed a mobile vaccination program after parental concerns about COVID-19 transmission and other social and economic effects from the pandemic led to reduced routine pediatric vaccination rates (Leibowitz et al. 2021). Similarly, another vaccine education outreach program cited the negative impact of stay-at-home orders, fears of contracting COVID-19 in medical settings, and general disruption of health care operations on well-child visits and routine childhood vaccinations (Deerin et al. 2022).

COVID-19 vaccine hesitancy and relaxed school vaccine requirements may also have impacted routine vaccination rates. COVID-19 vaccine hesitancy may have affected confidence in routine childhood vaccination and flu vaccination (referred to as a carryover effect) (CDC 2022j; Leuchter et al. 2022). Predominant sources of information on vaccination also impacted vaccine confidence: during the pandemic, people received more vaccine-related information from the news, internet, and social media and less information from primary care clinicians (American Academy of Family Physicians 2021). Relaxed vaccine requirements for remote students, reduced staffing in schools, and lower reporting and response rates from schools and parents may have also impacted reported routine vaccination rates in school-based data (Seither et al. 2022).

## B Routine vaccination programs

Our literature review identified a relatively small number of sources (six) describing programs focused on increasing routine vaccination rates during the COVID-19 pandemic. These programs cited the negative impact of the COVID-19 pandemic on routine vaccination as motivation for their efforts. Observing declines in routine vaccination rates, some federal programs and funders shifted some focus from COVID-19 to support local programs’ efforts. For example, the Office of Infectious Disease and HIV/AIDS Policy in OASH, HHS, launched a campaign to promote routine childhood immunizations, Catch-up to Get Ahead.

In this section, we discuss findings from the literature and key informant interviews on how programs used primary approaches and delivery strategies to attempt to improve routine vaccination rates, the implementation challenges they experienced, and their implementation strategies.

### 1 Primary approaches used for routine vaccination programs during the COVID-19 pandemic

While routine vaccination programs used some approaches that COVID-19 testing and vaccination programs used, routine vaccination programs also used traditional primary care settings to increase access to vaccinations. Unlike COVID-19 testing and vaccination programs, routine vaccination programs in our review did not use mass vaccination clinics or vaccination education events as primary approaches during the pandemic. Exhibit V.2. summarizes the routine program approaches described in the literature and by key informants.

Exhibit V.2 Primary approaches of routine vaccination programs during the COVID-19 pandemic

Approach | Description
Increase access to routine vaccinations
Vaccination in health care settings | Health care settings such as federally qualified health centers administered vaccines at well-child visits and other appointments, or established walk-in clinics to administer routine vaccines at their facilities.
Community vaccination clinics | Programs held vaccination clinics in convenient community sites where people congregate. The clinics relied on existing infrastructure from the community sites. These were usually recurring initiatives but also included one-time vaccination clinics (for example, at schools).
Mobile vaccination clinics | Traveling vans or mobile units brought vaccines to convenient locations in the community, and individuals came to the mobile unit to receive vaccines.
Increase awareness of and confidence in routine vaccinations
Vaccination education outreach | Programs conducted outreach to populations of focus to share educational information on vaccine-preventable diseases and routine vaccinations to address vaccine hesitancy or to promote and coordinate uptake of vaccines. Outreach methods included social media, phone calls, text messages, radio and television ads, and flyers.

Routine vaccination programs prioritized community-centered approaches and approaches in health care settings.

- Vaccination in health care settings. Clinical providers typically provide routine vaccinations for children and adults during primary care visits and other types of appointments. During the COVID-19 pandemic, key informants described continuing to use this approach in health care settings such as FQHCs and tribal health facilities. For example, a key informant from a federal agency reported that the tribal health facilities that it funds offered routine child and adult vaccines at all health care appointments, regardless of the reason for the visit. These tribal health facilities also began offering regular on-site walk-in clinics for routine vaccination.
- Community vaccination clinics. Like COVID-19 vaccination clinics, community clinics for routine vaccinations enabled programs to use community sites or community events to deliver vaccines more equitably and make them more convenient for community members. For example, one key informant’s CBO began offering routine adult vaccinations on-site at their community center in early 2023, after successfully using this approach for COVID-19 vaccination. Another key informant’s local health department used community vaccination sites established during the pandemic (such as those at libraries) to administer routine vaccines. Organizations that reported implementing this approach in key informant interviews included tribal health systems, a CBO, a state health department, and a local health department.
- Mobile vaccination clinics. Mobile vaccination clinics similarly enabled programs to make services more convenient and tailor them to the needs of specific populations. One program administered by FQHCs in partnership with a hospital that implemented mobile vaccination clinics found that this approach was particularly helpful for reaching families who had COVID-19 transmission concerns (Leibowitz et al. 2021). Routine vaccination programs in our scan that implemented mobile vaccination clinics were administered by FQHCs, a hospital, and a local health department.

Key informant spotlight: Using COVID-19 infrastructure for routine vaccines

One local health department used mobile units that had provided COVID-19 vaccines to provide routine vaccines in communities with the highest geographic barriers to access. The health department has used the mobile units to administer flu and mpox vaccines, as well as other health services and social supports. The health department also used sites at schools that it had originally established for COVID-19 vaccination to administer flu vaccines.

Vaccination education and outreach was another primary programmatic approach. This approach helped programs increase awareness of routine vaccines and combat declining rates during the pandemic. For example, a rural health care center in Colorado implemented a reminder message campaign for HPV vaccination to improve rates of appointment scheduling (Kepka et al. 2021). Some national programs explicitly implemented vaccine education outreach approaches to increase routine vaccination rates that declined due to the COVID-19 pandemic (Deerin et al. 2022; U.S. Department of Health Human Services 2021; March of Dimes 2021; National Foundation for Infectious Diseases 2022). Of the vaccine education outreach programs we identified, most were administered by national entities, such as federal agencies, national foundations and non-profit organizations, and large hospitals or health systems. Similarly, key informants described campaigns to promote routine vaccinations via email, text, print, and social media. One CBO working with tribal communities across three states also worked with schools to provide technical assistance and educational materials for administrators and nurses to talk about vaccines.

### 2 Strategies to facilitate delivery of routine vaccination programs during the COVID-19 pandemic

Like COVID-19 vaccination programs, routine vaccination programs used several key strategies to enhance the effectiveness of their primary approaches (Exhibit V.3). These strategies simultaneously worked to increase access to, awareness of, and confidence in vaccines.

Exhibit V.3 Strategies to facilitate delivery of routine vaccination programs during the COVID-19 pandemic

Strategy | Examples
Increase access to, awareness of, and confidence in routine vaccinations
Draw on strategies from COVID-19 for routine vaccination | - Telling personal stories (Key informants); - Streamlining check-in processes (Key informants); - Reducing wait times (Key informants); - Offering extended hours (Key informants)
Engage multilingual staff | - Diverse staff (Leibowitz et al. 2021); - Interpretation staff (Leibowitz et al. 2021)
Increase awareness of and confidence in routine vaccinations
Form partnerships to deliver messaging | - Partners disseminate vaccine messaging and advocacy (March of Dimes 2021)
Use multiple channels to increase reach of vaccination messaging | - Text message vaccine reminders (Kepka et al. 2021); - Email vaccine reminders (Kepka et al. 2021); - Social media (Deerin et al. 2022); - Postcards (Deerin et al. 2022); - Local newspaper (Deerin et al. 2022); - Radio (Deerin et al. 2022); - Patient education from providers (Key informants)
Other goals
Coordinate vaccination with other health services | - Preventive pediatric care (Leibowitz et al. 2021); - Physical examinations (Leibowitz et al. 2021)

Routine vaccination programs built upon strategies used to deliver COVID-19 vaccination services—or used strategies similar to those used for COVID-19—to enhance vaccine delivery and increase vaccine awareness and confidence.

- Key informants drew on messaging strategies and infrastructure used to promote and deliver COVID-19 vaccination, helping them enhance routine vaccination delivery services. For example, a key informant from an FQHC seeking to improve routine childhood vaccination rates found telling personal stories and testimonials to be an effective method to promote vaccine confidence for COVID-19. This informant (a clinician) began sharing with patients about getting their own children vaccinated against flu and other illnesses. The FQHC also incorporated process improvements from the COVID-19 vaccination rollout into routine vaccination efforts, such as streamlining check-in, reducing wait times, and offering expanded hours for vaccination. Another key informant from a federal agency reported that tribal health facilities implemented similar improvements, such as expanding evening and weekend hours and establishing standing times for walk-in vaccinations. In addition to drawing on process improvements developed for COVID-19 vaccination, some key informants also bundled routine vaccinations, like the flu vaccine, with COVID-19 vaccination at their community vaccination clinics.
- Like COVID-19 programs, one routine vaccination program in our review hired multilingual and diverse staff to facilitate communication with non-English speaking populations and enhance vaccine delivery. The program, administered by health centers and a hospital in Boston, Massachusetts, involved staff “who reflected the diversity of their patient population” to deliver mobile vaccine services (Leibowitz et al. 2021, p. 3). It also offered interpretation services on-site to ensure effective communication.

Like COVID-19 programs, routine vaccination programs used partnerships and specific dissemination strategies to augment primary approaches focused on increasing awareness of and confidence in routine vaccinations.

- Routine vaccination programs partnered with national, state, and community organizations to disseminate information and provide advocacy support. Partnerships with organizations that have a broader reach than programs augmented vaccine education outreach efforts (HHS 2021d; NFID 2022). For example, a national vaccine education outreach program that sought to educate families about recommended vaccines and no-cost access through the Vaccines for Children program proposed using a national network of partners, community leaders, health care providers, and influencers to support dissemination of educational information and advocacy (March of Dimes 2021).
- Programs used various channels to effectively disseminate routine vaccination information. This strategy supported programs’ efforts to schedule vaccination appointments (Kepka et al. 2021; Deerin et al. 2022). For example, one program that sought to increase HPV vaccination rates implemented an HPV vaccination reminder message campaign using text messages and email to contact parents or caregivers (Kepka et al. 2021). As part of an HHS-funded, federal program that promoted routine childhood immunizations, FQHCs had staff conduct on-site promotion at health centers; call patients; mail postcards and letters to patients; and use social media, local newspapers, radio, television, and email to promote vaccines (Deerin et al. 2022). Similarly, key informants described clinicians providing patient education on routine vaccination during medical appointments using techniques such as motivational interviewing.

Key informant spotlight: Community conversations to promote routine vaccination

A community-based organization focused on tribal populations in three states trained community members to share their vaccine-related experiences with their families, friends, and coworkers to encourage routine vaccination, and later COVID-19 vaccination. This organization also hosted community listening sessions led by tribal leaders and providers; they used learnings from these events to inform their education and outreach materials about routine vaccines, as well as the COVID-19 vaccine.

One program that implemented a mobile vaccination clinic also offered other health services to maximize access to vaccinations and preventive care visits (Leibowitz et al. 2021). Specifically, the program offered examinations and other preventive pediatric care to families who might not otherwise seek in-person care due to concerns about COVID-19 transmission.

### 3 Challenges to routine vaccination program implementation

Few of the routine vaccination programs in the literature we reviewed reported implementation challenges. Below we summarize the implementation challenges described in environmental scan sources, followed by the strategies programs used to facilitate program implementation.

Exhibit V.4 Implementation challenges and strategies of routine vaccination programs during the COVID-19 pandemic

Category | Challenges staff faced in program implementation | Strategies staff used to facilitate program implementation
Resources | Budget and funding constraints, staffing limitations, and issues with obtaining supplies posed a challenge to program implementation. | Training existing and additional personnel helped address resource challenges.
Operations and logistics | Lack of time to conduct vaccination activities posed a challenge to program implementation. | Conducting ongoing program monitoring and quality improvement and taking advantage of improvements made during the COVID-19 pandemic for routine vaccination efforts helped programs strengthen their operations.

While few routine vaccination programs reported implementation challenges, those that did faced resource limitations similar to COVID-19 programs. These limitations were compounded by the pandemic.

- A few key informants reported challenges with bundling routine vaccinations and COVID-19 vaccines due to different funding sources. For example, a CBO noted that routine vaccinations usually still had a cost or required insurance (which could be a barrier to their client population), unlike the COVID-19 vaccine. The CBO was able to overcome this challenge by partnering with its local health department, which was able to secure funding to provide these vaccines for free. A key informant from a federal agency noted that routine and COVID-19 vaccinations had different funding sources (as of March 2023), and different providers were authorized to distribute them, which made it difficult to fully coordinate distribution.
- Some routine vaccination programs faced staffing challenges. One program in the literature faced challenges staffing mobile vaccination clinics aimed at providing routine childhood vaccinations and preventive care visits (Leibowitz et al. 2021). A key informant from a federal agency noted that early in the pandemic, many immunization staff were pulled from their day jobs to work on COVID-19 vaccination efforts, which likely contributed to the decline in routine childhood immunizations during the pandemic.

Routine vaccination programs also faced operational and logistical challenges related to insufficient time to administer vaccines or conduct needed outreach. This was driven by the vaccine delivery approaches used by programs or was a general challenge for providers (Kepka et al. 2021; Leibowitz et al. 2021). For example, a program that implemented a mobile vaccination clinic found that mobile initiatives require more time for outreach and scheduling than traditional clinic visits (Leibowitz et al. 2021). Providers in another program reported that they often did not have enough time to administer vaccines (Kepka et al. 2021). Key informants also described staff being overwhelmed by the COVID-19 pandemic and not having time to focus on routine vaccination efforts. For example, one state health department shared that encouraging COVID-19 and influenza vaccines was “all our providers could handle,” rather than focusing on all routine vaccinations.

### 4 Strategies to facilitate routine vaccination program implementation

In this section we elaborate on the strategies introduced in Exhibit V.4 that programs used to facilitate implementation.

Programs invested in personnel who administer routine vaccination programs, helping to address resource challenges.

- Some programs trained their staff on specific vaccines and best practices for vaccine delivery. One program offered staff training about the HPV vaccine (Kepka et al. 2021; see spotlight box). Programs also provided training on how to educate recipients, how to communicate about their respective initiative, and how to schedule appointments (Kepka et al. 2021; Leibowitz et al. 2021). Key informants echoed these strategies; for example, one CBO trained providers on motivational interviewing to encourage routine vaccination for children. Additionally, a federal agency developed a new strategy—called E3, or Every patient, Every encounter, Every vaccine—to standardize practices among i health care providers and remind them to offer routine vaccinations to every patient, regardless of the reason for the visit.
- As a counterpoint to staff challenges caused or compounded by the pandemic, one key informant noted that investments in staff and partnerships during the pandemic will ultimately benefit routine vaccination programs. This informant from a federal agency noted that states have been able to substantially increase the infrastructure for adult vaccinations by increasing the number of staff and immunization providers they work with.

Program spotlight: Personnel training on human papillomavirus (HPV) vaccination

A program offered providers training about the HPV vaccine consisting of two one-hour long video call trainings on HPV vaccination systems, vaccine recommendations, and population-specific guidance. Providers were taught how to deliver a compelling and brief recommendation for the HPV vaccine to their patients (Kepka et al. 2021).

Routine vaccination programs drew on program feedback and investments in data infrastructure to strengthen operations.

- Some programs implemented quality improvement and evaluation efforts to learn from operational challenges. One program administered by health centers and a hospital conducted a quality improvement survey with families via telephone and had staff participate in a debrief regarding their experiences after the intervention (Leibowitz et al. 2021; see spotlight). Another program administered by a medical center implemented a pre- and post-intervention survey to assess the effect of its health care provider training efforts on provider knowledge of HPV, HPV vaccination, and barriers to vaccination (Kepka et al. 2021).
- Like investments in staff and partnerships, key informants noted that investments in data infrastructure during the COVID-19 pandemic will benefit routine vaccination programs. For example, a federal agency previously did not receive real-time data on any vaccinations but, because of the pandemic, has required that states must report all vaccine data in real time. Similarly, a CBO serving tribal populations in three states used pandemic funding to provide technical assistance on data reporting to smaller tribal organizations that provide routine vaccination services in addition to COVID-19 vaccinations. The CBO assisted the other organizations with new processes for reporting data to funders on activities implemented to improve vaccine confidence and uptake.

Program spotlight: Conducting quality improvement surverys

A program conducted a quality improvement survey of families who used their mobile vaccination clinics. Program staff conducted outreach and interviewed families via telephone. Survey data revealed that families experienced high levels of patient satisfaction and were likely to use mobile clinics again in the future.

Providers in the program also shared their experiences supporting the mobile clinics and reported that clear communication and cultural competency were crucial to the program’s success (Leibowitz et al. 2021).