# IV Key findings on COVID-19 vaccination

This section reviews COVID-19 vaccine types and guidelines as of April 2023 (Section IV.A), key changes to vaccination guidelines over time (Section IV.B), and equity implications of vaccine distribution throughout the pandemic (Section IV.C). Section IV.D summarizes COVID-19 vaccination programs’ primary approaches and delivery strategies, the implementation challenges they experienced, and the implementation strategies they used to overcome those barriers.

## A COVID-19 vaccine types and current vaccination guidelines

The FDA initially granted emergency use authorization for four COVID-19 vaccines. These vaccines included two mRNA (messenger ribonucleic acid) vaccines developed by Pfizer-BioNTech and Moderna, Johnson & Johnson’s Janssen viral vector vaccine, and the protein subunit Novavax (Adjuvanted) vaccine (CDC 2023e; FDA n.d.c). CDC issued a preferential recommendation for mRNA vaccines in December 2021. It fully approved the Pfizer BioNTech COVID-19 vaccine in August 2021 and the Moderna COVID-19 vaccine in January 2022 (CDC 2023a). For each vaccine, there is a recommended primary series, as well as a booster series. CDC distinguishes between original boosters, which were recommended in August 2021 to protect against the initial SARS-CoV-2 virus, and updated bivalent boosters, which were authorized by the FDA in September 2022 and provide additional protection against Omicron variants BA.4 and BA.5.

As of April 14, 2023, COVID-19 vaccination guidelines are based on age, vaccine type, and whether people are moderately or severely immunocompromised (CDC 2023e). Guidelines by age group for those who are not immunocompromised are as follows.^6^

- Children ages 17 and under: CDC recommends that children ages 17 and under receive two doses of the Moderna or Pfizer-BioNTech COVID-19 vaccine (primary series), with an updated booster shot at least two months after the last dose of the primary series. Children ages 12–17 are also eligible to receive the Novavax vaccine for their primary series, with an updated Pfizer or Moderna booster (CDC 2023e).
- Adults ages 18 and over: Recommendations are similar for adults ages 18 or over, but adults who completed a Novavax primary series may be eligible for an updated Novavax booster. In addition, the Johnson & Johnson vaccine is available to adults ages 18 or over but is not recommended as a first choice due to a risk of thrombosis with thrombocytopenia syndrome (CDC 2023e; CDC 2022f).

## B Changes in COVID-19 vaccination guidelines over time

COVID-19 vaccination guidelines evolved with the development and approval of vaccines for different age groups and as vaccines became available. COVID-19 vaccines were initially distributed under emergency authorization use and in phases for specific populations, due to limited supply (National Academies 2020; CDC 2023a). In December 2021, CDC and Advisory Committee on Immunization Practices (ACIP) released guidelines for phased vaccine allocation with populations prioritized for vaccination as follows: health care workers and residents of long-term care facilities (Phase 1a), people ages 75 or older and non-health-care essential workers (Phase 1b), people ages 65–74 years and ages 16–64 with medical conditions that put them at high-risk for COVID-19 (Phase 1c), and all others ages 16 years and older (Phase 2) (Dooling et al. 2020). Children under age 16 were not included in these initial phases because vaccines were not authorized for them at the time. Vaccines became widely available in May 2021 and were added to CDC’s routine vaccination schedules in February 2023 (The White House 2021a, Weixel 2023). Exhibit IV.1 provides a summary of changing guidelines throughout the pandemic.

Exhibit IV.1 Changes in COVID-19 vaccination guidelines December 2020-April 2023

A timeline infographic displays changes in COVID-19 vaccine guidelines 2020 to 2023, by month. The first guideline changes are in December 2020, when the CDC and the Advisory Committee on Immunization Practices recommended allocation of vaccine to different people, in phases States then implemented those recommendations for the Pfizer-BioNTech and Moderna vaccines. The last milestones shown are in February and March 2023 when CDC added COVID-19 vaccines to its routine vaccination schedules, and issued an emergency use authorization for bivalent booster doses for young children.

## C Equity implications of vaccine distribution

CDC and ACIP’s initial guidelines for phased administration of the COVID-19 vaccine, when vaccine supply was limited, were informed by equity-focused research (Dooling et al. 2020). This research included work by the National Academy of Sciences, Engineering and Medicine which outlined priority phases for vaccination and suggested equity considerations within each phase (National Academies 2020). CDC’s and ACIP’s guidelines also prioritized essential workers in early phases of vaccination, emphasizing that people from racial and ethnic groups experiencing disproportionate risk of COVID-19 were often overrepresented in these essential jobs (Dooling et al. 2020; CISA 2020). In addition, CDC launched programs such as Partnering for Vaccine Equity (P4VE) to support equity in adult vaccination (CDC 2020a).

Ultimately, states determined how vaccines would be allocated, leading to geographic variation in access. States primarily adhered to the CDC and ACIP guidelines for phased vaccine distribution. However, there was some variation primarily due to states adding additional groups in initial phases. States also rolled out the vaccine on different timelines, meaning access and availability to the vaccine initially varied by state (Kates et al. 2021). In addition, states took different approaches to vaccine mandates, resulting in differential vaccination rates for certain people and geographic areas (McGarry et al. 2022, Juarez et al. 2022).

In March 2021, the president stated a commitment to equitable and widespread vaccine distribution. Specifically, the president expressed a goal to make the vaccines available to all Americans (Phase 2) by May 2021 and announced plans to double the number of federal mass vaccination centers and pharmacies with COVID-19 vaccines, particularly in communities at disproportionate risk for COVID-19 (The White House 2021a, 2021b). At this time, CDC also released its COVID-19 Response Health Equity Strategy, which prioritizes (1) collecting data to monitor and identify differences in vaccination by age, race, ethnicity, sex and other demographic variables; (2) expanding culturally relevant vaccination programs and information; (3) addressing barriers to access; and (4) building capacity for vaccine distribution and delivery (CDC 2022a).

Key informant spotlight: Benefitting from the Public Readiness and Emergency Preparedness (PREP) Act

Several key informants reported that the PREP Act Declaration (issued March 2020) helped increase COVID-19 vaccination access by allowing pharmacists to administer COVID-19 vaccines, as well as routine vaccines. An informant from a federal agency explained that this was instrumental in expanding the pool of available vaccinators, especially given staffing shortages of nurses.

Following this announcement, several important programs and policies launched to support health equity. For example, the Health Resources and Services Administration (HRSA) launched programs to expand vaccine access in specific communities. These included (1) the Community-Based Outreach Program, which focused on building vaccine confidence through locally focused and culturally tailored outreach in partnership with CBOs (HRSA 2022a); (2) the Rural Health Clinic Vaccine Distribution and Vaccine Confidence Programs, focused on partnering with rural health clinics to increase vaccination (HRSA 2022f, 2022g); and (3) the Health Center COVID-19 Vaccine Program, to provide vaccines directly to FQHCs (HRSA 2022c). Analysis of three federal programs, including HRSA’s Health Center COVID-19 Vaccine Program, CDC’s Retail Pharmacy Program (2023h), and the Federal Emergency Management Agency (FEMA) Community Vaccination Center Pilot Site and Mobile Vaccination Program (FEMA 2021), found that these programs implemented equity-focused strategies, such as using population data on race and ethnicity when selecting vaccination sites (U.S. Government Accountability Office 2022).

## D COVID-19 Vaccination programs

As in Section III, this section presents findings on the COVID-19 vaccination programs we reviewed, including how they used primary approaches and delivery strategies to attempt to overcome barriers to vaccine use, the implementation challenges they experienced, and their implementation strategies.

### 1 Primary approaches used for COVID-19 vaccination programs

The primary approaches of the COVID-19 vaccination programs we identified in the scan intended to influence access to vaccination and awareness of and confidence in vaccination. Like COVID-19 testing programs, COVID-19 vaccination programs’ primary approaches to address access differed in terms of the travel or effort required for recipients to access services. They also differed in terms of the number of people they reached at a given time and whether they were recurring or one-time approaches. Programs in this review often combined approaches to increasing access with approaches to increasing awareness and confidence (Abdul-Mutakabbir et al. 2022; Le-Morawa et al. 2022). Programs focused on increasing awareness of and confidence in COVID-19 vaccinations that did not deliver vaccines used educational events and outreach to populations of focus (Gregory 2021; Association of American Medical Colleges. 2022; AuYoung et al. 2022; Peteet et al. 2022; Venegas-Murillo et al. 2022). Exhibit IV.2 summarizes COVID-19 vaccination programs’ primary approaches.

Exhibit IV.2 Primary approaches of COVID-19 vaccination programs

Approach | Description
Increase access to COVID-19 vaccinations
Mass vaccination clinics or events | Programs held large-scale vaccination clinics or events set up to provide a high volume of vaccinations in one location. These could be drive-through or walk-up events and can be recurring or one-time events. If they were recurring, they usually had a consistent time and place.
Vaccination in health care settings | Programs set up vaccination clinics in health care settings such as health centers, rural health clinics, and pharmacies.
Community vaccination clinics | Programs set up vaccination clinics in convenient community sites where people congregate. The clinics relied on existing infrastructure from the community site. These were usually recurring venue-based initiatives but also included one-time vaccination clinics set up at community events (for example, school sports events).
Mobile vaccination clinics | Traveling vans or mobile units brought vaccines to convenient locations in the community, and individuals came to the mobile unit to receive vaccines.
In-home vaccination | Mobile teams traveled to recipients and provided COVID-19 vaccinations in the recipients’ homes. These services supported homebound people who cannot travel to vaccination sites.
Increase awareness of and confidence in COVID-19 vaccinations
Vaccination education events | Educational events disseminated information about COVID-19 and COVID-19 vaccinations. These included webinars, forums, and town halls. They included both one-time and recurring events.
Vaccination education outreach | Programs conducted outreach to populations of focus as a primary approach, not related to an accompanying vaccination delivery effort. They shared educational information on COVID-19 and COVID-19 vaccinations and address vaccine hesitancy or promote and coordinate uptake of vaccines. Outreach methods included social media, phone calls, text messages, radio and television ads, and flyers.

COVID-19 vaccination programs implemented several approaches to deliver vaccines. These approaches were largely similar to those identified for testing, with the addition of approaches focused on increasing vaccination confidence.

- Mass vaccination clinics or events. Mass vaccination clinics or events, like mass testing events, are larger in scale than community vaccination clinics and enable programs to vaccinate many people in short periods of time. For example, one program serving the San Carlos Apache Tribe in Arizona found that its mass drive-through clinics had the biggest impact early in its vaccination campaign (Le-Morawa et al. 2022). Of the mass vaccination clinics or events we identified in the literature, most were administered by community-based organizations, local health departments (city or county health departments), health clinics, and tribal health departments.
- Vaccination in health care settings. Vaccination in health care settings allowed programs to leverage the established infrastructure, staff, and resources available in health care settings to deliver vaccines to communities. Health care settings included community health centers, (Public Health – Seattle and King County 2021), rural health clinics (Beste et al. 2021), retail pharmacies (Osibanjo et al. 2022), nursing homes (Feifer et al. 2021), and substance use disorder agencies (Washington et al. 2022). For example, a program in Clarkston, Georgia set up a recurring vaccination clinic directly outside of the primary health clinic to provide community members a consistent and familiar location (Malone et al. 2022). Of the programs we reviewed, most of those that implemented this approach were administered by health clinics, sometimes in partnership with CBOs, and local health departments.
- Community vaccination clinics. Community vaccination clinics helped programs more equitably distribute vaccinations by using convenient locations such as churches, businesses, schools, and sites where populations of focus gather such as food pantries and senior centers (Bigelow et al. 2022; New York State Department of Health 2020). Some programs implemented community vaccination clinics with consistent locations and times (Bigelow et al. 2022) and others held pop-up clinics to meet community needs (Relias Media 2021; Le-Morawa et al. 2022). Similarly, key informants described strategically choosing community vaccination sites such as libraries and public transportation centers, as well as various agencies providing social services to their populations of focus. Community vaccination clinics in the literature were most commonly administered by CBOs, followed by local health departments and state health departments.
- Mobile vaccination clinics. Like community vaccination clinics, mobile vaccination clinics enabled programs to provide COVID-19 vaccines more equitably by tailoring the site of the vaccination clinic to the needs of the program’s population of focus. For example, programs implemented mobile vaccination clinics at community sites like church parking lots (Abdul-Mutakabbir et al. 2022), parks and recreation centers (Alcendor et al. 2022a), or encampments (Rosen et al. 2023). Recognizing potential transportation barriers, one program, administered by a university, the San Francisco Department of Public Health, and local community-based organizations, sought to increase vaccination rates among Latinx individuals in San Francisco by setting up a vaccination site in a small parking lot near a busy transport hub (Marquez et al. 2021a). It remained open four days a week. Mobile vaccination clinics in the literature were most often administered by local health departments followed by academic institutions and community-based organizations.
- In-home vaccinations. In-home vaccination supported homebound people who could not travel to vaccination sites (Public Health - Seattle and King County 2021). For example, one multi-city program run by the Veterans Health Administration (VHA) sent off-site teams to vaccinate homebound veterans (Beste et al. 2021), and another program serving the San Carlos Apache tribe in Arizona offered in-home vaccinations to increase access (Le-Morawa et al. 2022). COVID-19 vaccination programs in the literature we reviewed did not implement in-home services as commonly as COVID-19 testing programs, but those that did were administered by CBOs, local health departments, large hospitals or health systems, health clinics, and tribal health departments.

Key informant spotlight: Federally qualified health center (FQHC)-sponsored community vaccination clinics

An FQHC partnered with five meatpacking plants in its service area to offer vaccination services onsite, as many of the FQHC’s patients were employed at the plants. The FQHC also partnered with a local food bank and a homeless shelter to offer regular on-site vaccination services in those locations.

COVID-19 vaccination programs also implemented stand-alone approaches to increase awareness of and confidence in COVID-19 vaccinations.

- Vaccination education events. Some programs implemented vaccine education events such as community town halls (AuYoung et al. 2022; Marquez et al. 2021a; Mathur and Dolgin 2022), webinars (Abdul- Mutakabbir et al. 2022; Peteet et al. 2022), or provider-led educational lessons for patients (Venegas-Murillo et al. 2022) in addition to conducting vaccine education outreach efforts as stand-alone approaches. Vaccination education events were most often administered by academic institutions, followed by CBOs, local health departments, and large hospitals or health systems.
- Vaccination education outreach. Several programs conducted vaccination education outreach as their primary focus, without an accompanying vaccination service component. These programs had providers or program staff call community members and provide education on COVID-19 vaccinations, used social media to dispel myths and boost confidence in vaccines, and created and posting flyers around the community (Marcell et al. 2022; Moore et al. 2022; AuYoung et al. 2022). One state-level campaign run by University of Washington, Seattle, created a website where providers, pregnant people, and community members could learn more about the risks of COVID-19 and the benefits of vaccination during pregnancy (Marcell et al. 2022).

Program spotlight: COVID-19 educational webinars

A program partnered with faith organizations and a Latinx organization led by community health workers to hold a series of educational webinars to build community trust and vaccine confidence among non-Latinx Black and Latinx community members (Abdul-Mutakabbir et al. 2022).

### 2 Strategies to facilitate delivery of COVID-19 vaccination programs

Like COVID-19 testing programs, COVID-19 vaccination programs used a combination of strategies to enhance the effectiveness of their primary approaches. Exhibit IV.3 and the following section are organized by the primary goal(s) of the delivery strategy. Strategies that worked to increase access, awareness, and confidence at the same time were most common. Programs also pursued strategies focused on increasing awareness of and confidence in vaccines and other strategies focused on increasing access. Within each of these sections, we present strategies according to how commonly they appeared in the literature we reviewed.

Exhibit IV.3 Strategies to facilitate delivery of COVID-19 vaccination programs

Strategy | Examples
Increase access to, awareness of, and confidence in COVID-19 vaccinations
Form community partnerships to deliver COVID-19 vaccines and messaging | - Partnerships with community-based organizations, such as faith-based organizations and community health organizations (Faherty et al. 2022); - Peer vaccine ambassadors (Marquez et al. 2021a); - Community advocates (Mathur and Dolgin 2022)
Engage multilingual staff | - In-person translators (Malone et al. 2022); - Phone translation services (Malone et al. 2022)
Coordinating with routine vaccination efforts | - Using routine immunization infrastructure (Gregory 2021)
Increase awareness of and confidence in COVID-19 vaccinations
Develop population-specific or culturally tailored messaging | - Messaging in multiple languages (Alcendor et al. 2022a); - Culturally competent messaging (Feifer et al. 2021); - Motivational interviewing and trauma-informed messaging (e.g., Rosen et al. 2023)
Use multiple channels to increase reach of vaccination messaging | - Flyers, infographics, and Facebook Live sessions (Alcendor et al. 2022a); - Radio (Marquez et al. 2021a); - Phone calls (Relias Media 2021); - Street outreach (Bigelow et al. 2022); - Door-to-door campaigns (Relias Media 2021)
Increase access to COVID-19 vaccinations
Offer walk-up options and expand hours | - Expanded operating hours (Relias Media 2021); - Walk-up appointments (Malone et al. 2022); - Individualized registration processes (Marquez et al. 2021a)
Reduce documentation requirements for vaccination | - No requirement of proof of residency, vaccine eligibility, or health insurance status (Marquez et al. 2021a)
Provide transportation assistance | - Transportation coordination services (Malone et al. 2022); - Partnerships with ride-share apps (key informants)
Increase uptake of COVID-19 vaccinations
Offer financial incentives | Gift cards (key informants)
Other goals
Coordinate vaccination with other health and social services to meet health-related social needs | - Referrals to social and case management supports (Gupta et al. 2022); - Food supports (Relias Media 2021)

Like testing programs, most COVID-19 vaccination programs implemented strategies to address all three goals related to COVID-19 vaccination, placing priority on partnerships.

- Programs partnered with trusted community leaders, CBOs, and community members to deliver COVID-19 vaccines and messaging. This helped programs increase their reach among populations of focus (Faherty et al. 2022; Faherty et al. 2021). For example, through the Rockefeller Foundation’s U.S. Equity First Vaccination Initiative, partners like CBOs made nearly 15 million connections with community members to disseminate accurate COVID-19 information and held more than 4,000 vaccination events (Faherty et al. 2022). Another program, funded by the NIH and administered by California’s statewide alliance, STOP COVID-19 CA, leveraged community partnerships and brought together 11 academic sites and 75 community partners to learn from each other and better understand community concerns about the COVID-19 vaccine, misinformation, and to address racial and ethnic inequities in vaccine hesitancy and uptake (AuYoung et al. 2022). As another example, an Illinois program focused on increasing COVID-19 vaccination rates among people experiencing homelessness partnered with advocates to engage community members at housing projects, soup kitchens, and other local events. They found that directly asking community members about their needs, rather than taking a top-down approach, fostered trust and increased vaccine access (Mathur and Dolgin 2022). Another program administered by an academic institution that sought to increase vaccination rates within non-Latinx Black and Latinx communities in San Bernardino County, California partnered with faith and community leaders to host educational webinars to address vaccine hesitancy (Abdul-Mutakabbir et al. 2022). One program administered by an academic hospital, the San Francisco Department of Public Health, and community members had peer vaccine ambassadors speak with unvaccinated friends and family about the COVID-19 vaccine, share their positive experiences at the community vaccination site, and provide information about how to register for vaccination (Marquez et al. 2021a).
- Several programs serving immigrant and non-English speaking communities had multilingual staff or translators available on site to ensure accessibility of services. This helped programs reach Latinx communities (Faherty et al. 2022; Gupta et al. 2022). One program in San Francisco, California had Spanish-speaking Latinx community members conduct educational outreach such as going door-to-door and hosting townhalls to raise awareness about vaccine eligibility, disseminate vaccine education, and promote the program’s vaccination site (Marquez et al. 2021a). Another program administered by a primary care clinic in Clarkson, Georgia used a combination of in-person translators and phone translation services to increase access to COVID-19 vaccinations for non-English speaking populations (Malone et al. 2022). Likewise, one key informant described their health system’s community health worker program in a tribal nation that paired community health workers with native speakers of the local tribal language to promote COVID-19 vaccination and testing via outreach.
- COVID-19 vaccination programs took advantage of routine vaccination services and messaging. For example, a multi-state program using pharmacists to provide COVID-19 vaccines to American Indians and Alaska Natives found that existing infrastructure from a previous mass vaccination program designed to improve routine immunization rates among Native American children facilitated a successful COVID-19 vaccination rollout (Gregory 2021). Similarly, key informants described efforts to incorporate COVID-19 vaccines into routine vaccination delivery or messaging. A CBO serving tribal populations in several states that previously focused on routine vaccination efforts used some of its strategies (such as peer education about vaccination) to also promote COVID-19 vaccination. As COVID-19 vaccines become part of a more routine vaccination schedule, with similar funding sources to other vaccinations, bundling services or messaging may become a more prevalent strategy. For example, a key informant representing a health system in a tribal nation described incorporating COVID-19 vaccinations into flu vaccine clinics offered in the community during the fall and winter months.

Key informant spotlight: Sharing personal stories of vaccination

A community-based organization that focuses on media strategies and works across several states captured stories from about 500 people talking about their COVID-19 vaccination experiences and then shared those stories at events hosted in conjunction with community partners. The key informant noted that having “real people” share their stories of COVID-19 vaccination was more effective than testimonials from celebrities or others outside the community.

Key informant spotlight: Bundling information on COVID-19 vaccination with routine vaccination

A key informant from a foundation with national reach reported that incorporating information about COVID-19 into routine vaccination messaging was effective, given that “people are just done with hearing about COVID.” The key informant believed that sharing information more broadly about vaccinations in general, including COVID-19, softened the message and made it more appealing to people who may have otherwise been hesitant to engage.

Programs developed population-specific messaging strategies to increase vaccine awareness and confidence.

- Programs developed and translated culturally tailored messaging to ensure the relevance and accessibility of COVID-19 information for their populations of focus. Programs developed messaging in multiple languages to address COVID-19 misinformation among community members who speak English as a second language (Alcendor et al. 2022a). One program administered by the state health department, a health system, faith-based groups, and community-based organizations in Baltimore, Maryland advertised bilingual hotline numbers through Spanish-language local media outlets (Bigelow et al. 2022). Another program in California also developed tailored materials that were informed by the local and contextual needs of communities, such as whether they were farmworker or urban communities (AuYoung 2022). Several programs also used trusted messengers from the same backgrounds as communities of focus. These messengers were able to have culturally relevant conversations about COVID-19 vaccination with other community members. For example, one national program administered by a long-term care provider that sought to increase vaccine confidence among Black and Latinx nursing home staff had nursing leaders from racially diverse backgrounds offer small group discussions and one-on-one conversations to answer culturally sensitive questions and increase vaccine acceptance (Feifer et al. 2021). Providing early vaccination to nursing home staff was enabled by the CDC’s Pharmacy Partnership for Long-Term Care Program. Another program in Los Angeles County used providers trained in motivational interviewing and trauma- informed care to provide COVID-19 vaccine education and administration (Rosen et al. 2023).
- Programs used a broad range of communication channels, from social media to mass media to door-to-door outreach. This strategy helped programs promote vaccination services and increase the reach of their messaging. For example, one program administered by an academic institution, the state health department, and community-based organizations in Tennessee developed flyers, infographics, and held Facebook Live sessions focused on vaccine safety and efficacy to address COVID-19 misinformation (Alcendor et al. 2022a). Other programs specifically disseminated their COVID-19 vaccination messaging on Spanish-language radio shows (Marquez et al. 2021a; AuYoung et al. 2022). Additional outreach methods included phone calls (Relias Media 2021; Gregory 2021), street outreach (Bigelow et al. 2022), and door-to-door campaigns (Relias Media 2021; Massachusetts Department of Public Health 2021; Marquez et al. 2021a). Similarly, key informants echoed strategies of disseminating messages through culturally specific media channels and hosting community conversations to address vaccine hesitancy.

Key informant spotlight: Using trusted messengers

A local health department implemented a trusted messenger program to increase vaccine awareness and acceptance. The health department trained individuals representative of the local population, such as community health workers, to speak with people about COVID-19 vaccination at community events and provided small grants that these individuals could use to develop and implement vaccine awareness campaigns in their communities. The key informant noted that using trusted messengers helped overcome community mistrust in medical institutions due to historical marginalization.

Key informant spotlight: Social media strategies to promote vaccine confidence

A foundation with national reach partnered with media agencies to create campaigns to identify, monitor, and reduce vaccine hesitancy among racial and ethnic minority groups. Media agencies created materials without branding so that community-based organizations could use their organizational logos and launch them on their social media pages. The lack of centralized branding was a deliberate effort to avoid impressions of government agency involvement, as the foundation recognized that many racial and ethnic minority groups have a historically informed distrust of government and institutional involvement in their health.

Programs provided participants with additional supports to overcome barriers to services and enhance availability of and access to COVID-19 vaccinations.

- Programs offered extended or shifted hours and walk-in appointments to accommodate community members’ working schedules and inability to take time off from work. For example, staff from the Planned Parenthood COVID-19 Vaccination Campaign expanded the operating hours of their vaccine clinics to better serve people who finish their working day in the evening and are unable to take time off (Relias Media 2021). Complicated scheduling and registration processes can also deter individuals who might have unconventional working schedules or do not have time to register for an appointment in advance. To address this, several programs offered walk-in appointments or individualized registration processes that allowed for community members to bypass registration forms and phone lines (Malone et al. 2022; Marquez et al. 2021a; Faherty et al. 2021). Similarly, a key informant’s FQHC offered COVID-19 vaccine appointments on evenings and weekends and provided on-site vaccinations at major employers and social service organizations to increase access among the clinic’s patient population.
- Several programs provided COVID-19 vaccinations without requiring identification or proof of insurance, residency, or occupation to increase vaccine access among low-income and immigrant populations. For example, some programs primarily serving Latinx communities provided COVID-19 vaccinations without requiring community members to provide proof of residency, vaccine eligibility, or health insurance status (Marquez et al. 2021a) or identification or proof of occupation (Bigelow et al. 2022). One mobile vaccination program in New York offered free services to all patients, regardless of insurance status (Association of American Medical Colleges 2022). Several key informants from organizations serving people without documentation implemented these strategies as well. For example, one key informant from a CBO in a large city noted that it assured its clients receiving COVID-19 vaccinations that none of their personal data would be shared. The informant also believed its clients were more comfortable receiving vaccinations at the CBO’s community center, because they perceived it as a safe space, rather than at a government facility such as a health department.
- A few programs offered recipients transportation assistance. For example, one national program planned to have health insurance providers coordinate transportation services for senior patients (American’s Health Insurance Plans 2021), and another program’s community engagement coordinator collaborated with community partners to help recipients register for and access transportation to vaccine appointments in Clarkston, Georgia (Malone et al. 2022). A few key informants described partnering with ride-share apps; for example, a national pharmacy retailer partnered with Lyft to provide free or discounted rides for clients to vaccine appointments. Similarly, a CBO partnered with ride-share apps to help transport clients to vaccine appointments at clinics offered through the city health department.

Programs offered financial incentives to increase uptake for low-income recipients. Only a few programs identified in the literature provided financial incentives to increase vaccine uptake among low-income communities (Rosen et al. 2023; Relias Media 2021; Faherty et al. 2021). In contrast, offering financial incentives was common among key informants’ organizations (including CBOs, health centers, and state and local health departments), usually in the form of gift cards, ranging in value from $25 to $300. One key informant from a federal agency noted that there was a high level of interest in providing incentives for COVID-19 vaccination, including from the White House, which may have prompted many programs to offer vaccine incentives. Key informants noted that offering gift cards helped to offset some financial barriers to vaccination, such as money for gas to drive to vaccination events.

Finally, some programs worked to address social and other health needs while providing vaccine services. A few vaccination programs identified in the literature provided additional services or referrals to address social and other health care needs such as case management, food supports, ride vouchers, COVID-19 tests, contact tracing, and other preventive health care services (Gregory et al. 2021; Gupta et al. 2022; Ahmad et al. 2022; Mathur et al. 2022). Several key informants’ organizations also provided services to meet an identified need in their community, such as food assistance. For example, CBOs and local health departments partnered with food pantries or mobile farmer’s markets to distribute food at vaccination events. Other programs addressed unique needs in their community; for example, one CBO partnered with a local organization to provide legal aid at vaccination events.

### 3 Challenges to COVID-19 vaccination program implementation

Like COVID-19 testing programs, COVID-19 vaccination programs faced implementation challenges related to insufficient resources and inefficient program operations and logistics. In this section, we describe these challenges. In the following section, we discuss the strategies program personnel used to facilitate program implementation.

Exhibit IV.4 Implementation challenges and strategies of COVID-19 vaccination programs

Category | Challenges staff faced in program implementation | Strategies staff used to facilitate program implementation
Resources | Budget and funding constraints, staffing limitations, and issues with meeting vaccine storage and handling requirements posed a challenge to program implementation. | Training existing and additional personnel and volunteers, relying on technical assistance from funders or government agencies, and taking advantage of flexibility from funders to implement innovative strategies helped programs overcome resource limitations.
Operations and logistics | Issues with patient tracking, site-specific challenges, and inconsistent information sharing decreased efficiency of program operations. | Conducting careful planning prior to program rollout and conducting ongoing program monitoring and quality improvement helped programs strengthen their operations.

Programs commonly faced resource challenges.

- Some key informants reported insufficient funding, while others struggled to use the amount of funding that was available. For example, one CBO struggled with limited funding availability at the beginning of the pandemic and restrictions on how grant funds could be used (for example, they could not be used to purchase vaccine incentives). Conversely, even when sufficient funding was available, organizations sometimes struggled to use large amounts of funding in short periods of time. For example, a respondent from a federal agency noted that during the COVID-19 pandemic, there was more funding going to tribal jurisdictions than ever before, and some grantees experienced challenges quickly expanding their staffing and operations in response.
- Several programs faced staffing challenges that made it difficult for programs to effectively reach community members. For example, some programs had insufficient staff to implement additional vaccination sites and more staff-intense modes of vaccine delivery, such as personalized telephone outreach and door-to-door campaigns (Beste et al. 2021; Le-Morawa et al. 2022). Another program that used pharmacists to provide vaccines to Medicaid-insured populations faced staffing challenges in retail pharmacies (Osibanjo et al. 2022; see spotlight). Some key informants also reported staffing challenges, both with hiring new staff and utilizing resources and meeting grant reporting requirements due to limited staff capacity.
- Insufficient or unpredictable vaccine supply, as well as requirements for storing and handling vaccines, hindered program activities. Programs had to develop strategies to minimize disruption for community members (Beste et al. 2021; Public Health—Seattle and King County 2021). For example, one program that delivered vaccines to veterans struggled with inconsistent vaccine supply and had to maintain constant communication with recipients and partners to keep them apprised of the availability of vaccines (Beste et al. 2021). A key informant from a national retail pharmacy chain shared that ensuring that transportation trucks and pharmacies had the capability to store vaccines (for example, having enough ultracold freezers) was a major challenge.

Spotlight on staffing challenges and solutions

Challenge: A program that provided vaccines to Medicaid-insured populations through retail pharmacists faced staffing challenges due to competing demands for pharmacists’ time, including their responsibilities to provide other vaccinations and fill prescriptions. At times, pharmacists needed to conduct outreach to unvaccinated individuals but did not have the capacity to do so.

Solution: The program used a rapid response team composed of nurses and care management staff to conduct scheduling outreach on behalf of pharmacists (Osibanjo et al. 2022).

Programs also faced operational and logistical challenges that hindered appropriate vaccine delivery and messaging.

- Some regional and state programs faced challenges around accessing and sharing patient vaccination data. One program administered by a regional Veteran’s Affairs health care system reported being unable to access data on vaccinations that veterans received outside of the VHA because the VHA and state immunization systems are unable to exchange data (Beste et al. 2021). This meant that some veterans received multiple outreach communications despite being vaccinated. Similarly, another program administered by a health plan in Oregon that serves Medicaid found that data lags between the county and pharmacies meant adult care home vaccinators did not always know whether a person had already been vaccinated, making it difficult to identify priority adult care homes for vaccination (Osibanjo et al. 2022).
- Inconsistent information sharing was also a challenge. A state-level program in California in our review found that the lack of infrastructure for consistent information sharing across federal, state, and county agencies made it difficult to understand and communicate the rapidly changing COVID-19 guidelines to its community (AuYoung et al. 2022).
- Several programs that implemented vaccination clinics encountered challenges related to characteristics of their vaccination sites. For example, one program serving tribal reservations in rural settings faced difficulties transporting vaccines (Gregory 2021), and another program serving the San Carlos Apache Tribe struggled to implement mass vaccination events due to inconsistent wireless connectivity (Le-Morawa et al. 2022). Another program in Los Angeles, California faced difficulties implementing community vaccination clinics for unsheltered people experiencing homelessness due to frequent encampment sweeps (Choi et al. 2022; Rosen et al. 2023).

### 4 Strategies to facilitate COVID-19 vaccination program implementation

In this section, we elaborate on the strategies program personnel used to facilitate program implementation introduced in Exhibit IV.4.

While most programs did not describe implementation strategies, those that did commonly used strategies to alleviate resource constraints.

- Some programs trained additional staff and volunteers to expand their capacity or to incorporate new program approaches. For example, as part of the COVID-19 vaccine rollout in the San Carlos Apache Tribe, a program offered trainings with support from FEMA on door-to-door vaccination campaigns (Le-Morawa et al. 2022). Trainings also provided personnel (including staff and volunteers) with information on COVID-19 symptoms, transmission, guidelines, vaccine efficacy, and guidance around how to communicate with certain populations (Marquez et al. 2021a; Beste et al. 2021; Faherty et al. 2022; Abdul-Mutakabbir et al. 2022). One neighborhood vaccination program provided site staff COVID-19 education and ongoing refresher trainings that would enable them to answer community questions and address concerns (Marquez et al. 2021a). Key informants also emphasized the importance of staff training; for example, one FQHC aimed for all its clinical staff to become so-called vaccine advocates.
- Key informants valued the technical assistance that they received from funders or government agencies. These included trainings on topics such as effective outreach and messaging to promote COVID-19 vaccines, community engagement strategies, addressing vaccine hesitancy, data and metrics to inform program delivery (such as the Social Vulnerability Index (https://www.atsdr.cdc.gov/placeandhealth/svi/index.html)), addressing staff burnout, and sustainability planning. In addition, several CBOs reported their technical assistance providers facilitated connections to local clinical or public health partners that were willing to co-host vaccination events. Some CBOs also had regular meetings with their cohort of grantees implementing similar programs, which was useful for sharing challenges and lessons learned. Key informants that reported the benefits of technical assistance commonly represented CBOs and health departments.
- Several key informants took advantage of flexibilities in their funding sources when implementing COVID-19 vaccination strategies. For example, a key informant from a federal agency noted that its awardees used COVID-19 vaccination funds to purchase vehicles (to offer mobile vaccination) or provide vaccine incentives; using funding for these activities as part of routine vaccination programs was not allowed prior to the pandemic. A state-wide program in California identified reducing bureaucratic obstacles to obtaining funding as a key strategy to minimize the administrative burden on community organizations (AuYoung et al. 2022). In addition to funding, some key informants (primarily from CBOs) reported receiving resources such as vaccines from local health agencies or clinical partners, which enabled them to use their grant funding for other purposes, such as community outreach.

Key informant spotlight: Training pharmacists

- A national pharmacy retailer partnered with community-based organizations to hold community dialogue events in major cities to gather community feedback about the COVID-19 vaccine; it then used learnings from the events to train pharmacists to talk about the vaccine with clients.
- A national pharmacy association provided educational web-based resources to community pharmacists about increasing COVID-19 vaccine confidence among their patients. The resources covered a range of topics intended to address concerns about and build confidence in the COVID-19 vaccines.

Programs used other strategies to overcome operational and logistical challenges, including careful implementation planning and ongoing quality improvement.

- Program planning enabled a smoother vaccine rollout. Program planning centered around vaccination prioritization strategies, obtaining and storing vaccine supply, and outreach and education strategies (Le-Morawa et al. 2022; Gregory 2021; New York State Department of Health 2020; Peteet et al. 2022; Feifer et al. 2021). For example, prior to the COVID-19 vaccine rollout in the San Carlos Apache Tribe, program staff acquired an ultracold freezer to store vaccines, developed a playbook to administer vaccines based on ACIP guidelines, identified high-priority individuals for vaccination, and developed call lists for future community outreach (Le-Morawa et al. 2022).
- A few programs in the literature, as well as several key informants’ organizations, conducted ongoing monitoring and quality improvement strategies during program implementation. Programs used findings from their monitoring to identify lags in vaccination across zip codes and communities and inform their vaccine delivery and messaging approaches. For example, the Puget Sound Veterans Affairs Health Care System Vaccination Drive team regularly monitored vaccine equity by comparing the cumulative proportion of individuals vaccinated by race and ethnicity, sex, and rural status within defined age groups. The team then discussed findings and developed proactive, tailored interventions focusing on equitable vaccine delivery (Beste et al. 2021). Another mobile vaccination clinic used ongoing quality improvement to identify disparities in access across groups, evaluate outreach strategies, and understand drivers of vaccine hesitancy (Rosen et al. 2023). The program then developed educational pamphlets and games to address the most common reasons for hesitancy. Similarly, key informants from state and local health departments, as well as a federal funder and a national pharmacy retailer, described regularly reviewing COVID-19 vaccination rates and tracking COVID-19 outbreaks among the communities they serve and using these data to focus their vaccination efforts.

Key informant spotlight: Clinician report cards

A federally qualified health center developed a report card for every clinician that assessed COVID-19 vaccination rates for each clinician’s patient panel. The report card also assessed the rate of patients who came in unvaccinated and “converted” by agreeing to receive the vaccine. The key informant noted that this program helped foster a healthy sense of competition among clinicians.

6 There are specific recommendations for people who are severely or moderately immunocompromised, which are outlined further at https://www.cdc.gov/coronavirus/2019-ncov/vaccines/recommendations/immuno.html.