# III Key findings on COVID-19 testing

This section first presents background on COVID-19 testing, including the testing methods and types of tests currently available and the latest COVID-19 testing guidelines (Section III.A), and how testing guidelines have changed over time as the COVID-19 pandemic and response efforts evolved (Section III.B). Section III.C presents common approaches and strategies used to deliver COVID-19 testing services, challenges programs faced in implementing testing programs, and strategies programs used to overcome those challenges.

## A COVID-19 testing methods, types of tests, and reporting of test data

Diagnostic, screening, and surveillance testing are the three main COVID-19 testing methods. Diagnostic testing identifies a current COVID-19 infection for individuals, particularly for people who have symptoms or were recently exposed. Screening testing identifies infections among groups who may be at higher risk for COVID-19 and are performed regardless of symptoms or exposure. Surveillance testing focuses on ongoing monitoring and collection of de-identified testing data to look for outbreaks of COVID-19 at a population level (FDA n.d.a; CDC 2022k; APHL n.d.).

Molecular and antigen COVID-19 tests are used for diagnosis, screening, and surveillance. Other tests, including antibody tests, are used primarily for surveillance. As described further in Section III.B, types of tests and testing strategies evolved with the introduction of new technology, availability of tests, and organizational capacity for testing.

- Molecular tests detect ribonucleic acid (RNA), a genetic material from the SARS-CoV-2 virus that causes COVID-19 (APHL n.d.). These tests include polymerase chain reaction (PCR) tests and other nucleic acid amplification tests and are generally performed in a laboratory (FDA n.d.b). These tests are considered the most accurate. However, because RNA can stay in the body for up to 90 days, these tests are not recommended for people who tested positive for COVID-19 in the past 90 days (CDC 2022c).
- Antigen tests produce rapid results, typically within 30 minutes, and can be at-home tests or self-tests (CDC 2022c). Because antigen tests are more likely to produce false negative results, the FDA recommends repeat testing after a negative antigen test (FDA 2022a).
- Other types of COVID-19 tests include antibody (or serology) tests, which measure whether people were at one time infected with COVID-19. Because they cannot distinguish between current or past infections, these are not diagnostic tests, but they can be used for general surveillance (FDA n.d.b).

State, local, tribal, and territorial health departments require reporting for molecular and antigen tests, if they are performed in specific health care settings. Clinical Laboratory Improvement Amendments (CLIA)-certified hospitals, health care providers, and laboratories are required to report positive diagnostic and screening test results to patients and to their state, local, tribal, or territorial health department. This includes the results of nucleic acid amplification tests or molecular tests and of antigen test results. If tests are performed outside of a CLIA-certified facility (such as self-tests) or if tests are not FDA-authorized, results may be reported to the health department upon request, if they are de-identified and used for surveillance purposes only. After receiving data, health departments have the option to voluntarily submit de-identified case data to CDC for national surveillance through the National Notifiable Diseases Surveillance System (CDC 2022k). CDC then displays state and national case counts in a COVID Data Tracker. While health departments may use self-tests for surveillance purposes, national surveillance data does not include positive self-tests or other tests performed outside of CLIA-certified providers (CDC 2022d).

## B Changes in COVID-19 testing guidelines over time

COVID-19 testing guidelines have evolved rapidly from 2020 to the present, influenced by changing science and key milestones such as the (1) development of testing and vaccine technology, (2) introduction of policies and funding to support expanded testing, and (3) implementation of federal programs to expand testing capacity. Exhibit III.1 provides an overview of testing accomplishments and milestones that represented turning points in the COVID-19 response, as well as changes in guidelines for using various tests and testing modalities, that were influenced by these milestones. We describe these changes and the current COVID-19 testing guidelines further in the text below.

Exhibit III.1 Summary of COVID-19 testing milestones and guidelines February 2020-July 2022

A timeline infographic displays key milestones and changes to COVID-19 testing guidance from 2020 to 2022 Key milestones in COVID-19 testing are shown on the left side, starting in February 2020 with an emergency use authorization from the FDA for a CDC diagnostic test Changes to testing guidance are shown on the right, starting with CDC guidance for testing exposed and symptomatic patients in February 2020. The graphic shows different testing milestones and changes ta guidance by month The last key milestone is in July 2022 when Quest Diagnostics offered free COVID-19 testing to uninsured people as part of CDC’s Increasing community Access to testing program. The last guidance change was in October 2021, when CDC recommended testing 5-7 days after close contact with someone who has COVID-19, regardless of vaccination status.

Initial guidelines for COVID-19 testing reflected limited testing supply and recommended only performing diagnostic testing for priority populations. In February 2020, CDC required providers to report patients who either (1) had fever or respiratory illness and close contact with someone who had COVID-19 or (2) had fever and respiratory illness and recently traveled from China (CDC 2020b). Diagnostic testing for these patients could only be completed using CDC test kits analyzed at CDC laboratories. To support increased testing, the FDA released a policy in late February allowing some laboratories to use tests before they were authorized for emergency use (FDA 2020). Following this policy, CDC expanded its guidelines slightly to prioritize testing for people who were (1) hospitalized with symptoms, (2) immunocompromised or otherwise at higher risk for poor outcomes from COVID-19, or (3) in close contact with confirmed COVID-19 cases (CDC 2020k).

As new COVID-19 tests were authorized for use and testing capacity expanded, populations prioritized for testing also expanded. In June 2020, CDC recommended testing for all close contacts of people with COVID-19, regardless of symptoms, and suggested regularly testing asymptomatic people in high-density living situations such as shelters, nursing homes, or long-term care facilities (CDC 2020d). In March of 2021, CDC noted the expanded availability of tests and expanded its screening testing guidance, referring to screening of asymptomatic people as a key strategy in COVID-19 prevention, particularly in communities or settings such as schools with high levels of transmission (CDC 2021h).

CDC continues to change its testing guidelines as research on COVID-19 evolves. For example, as COVID-19 vaccines became widely available, CDC updated guidelines to note that only unvaccinated close contacts needed to be tested. However, the agency later reversed this change with new research demonstrating that asymptomatic vaccinated people could still transmit the SARS-CoV-2 Delta variant (CDC 2021h; Haroun and Brueck 2021; CDC 2021g). CDC also made more recent updates to de-emphasize screening in certain situations, based on research suggesting that this may be less cost-effective in settings with low rates of COVID-19 (Goodman and Cohen 2022; Massetti et al. 2022).

As of April 14, 2023, CDC recommends diagnostic testing for people with symptoms of or exposure to COVID-19 and screening testing in specific high-risk scenarios. CDC recommends (1) testing immediately if experiencing symptoms of COVID-19, (2) testing at least five days after exposure to COVID-19, and (3) considering testing before visiting someone who is at risk for severe COVID-19 (CDC 2022c). Screening testing recommendations are based on COVID-19 community levels. Community levels (low, medium, and high) help to classify the burden of COVID-19 in counties based on case and hospitalization data (CDC 2022i). CDC outlines prevention and testing strategies at each community level. While all communities are encouraged to provide access to testing, including at-home tests, CDC also recommends that communities with medium or high levels consider screening testing in high-risk settings such as schools, assisted living facilities, correctional facilities, and homeless shelters (CDC 2022b, 2022g).

CDC’s current guidelines also emphasize the importance of providing affordable, quality testing, with timely results for racial and ethnic minority communities, rural communities, and other groups experiencing inequities (CDC 2022g, 2023c). Recognizing that systemic health and social inequities influence disparities in COVID-19 burden as well as access to vaccination and testing, CDC established a COVID-19 Response Health Equity Strategy (CDC 2022a). The testing-related elements of the strategy include plans to (1) collect data to monitor and identify differences in testing by age, race, ethnicity, sex, and other demographic variables; (2) expand culturally relevant testing programs; (3) disseminate culturally relevant materials and practices to frontline workers serving communities experiencing disparities; and (4) build a more diverse and representative COVID-19 response workforce.

## C COVID-19 testing programs

Despite new testing technologies and evolutions in testing practices and guidelines, testing rates have shown inequitable uptake in different communities due to the barriers discussed in Section II.B (Pond et al. 2022; Rader et al. 2022). A primary goal of this environmental scan is to understand how public and private programs attempted to overcome these barriers and reduce inequities. In this section, we discuss the primary approaches and delivery strategies reported by COVID-19 testing programs that we reviewed, as well as the barriers to implementation they experienced and the implementation strategies they used to overcome those barriers.

### 1 Primary approaches used for COVID-19 testing programs

Programs’ primary approaches to increase COVID-19 testing identified in the scan all addressed access to testing, and fell along a continuum in terms of the travel required of test recipients. On one end of this continuum, centralized testing sites required test recipients to travel, often outside of their neighborhoods, and on the other end of the continuum, programs brought tests to recipients’ homes. We use travel to categorize these approaches because it represents the effort required to access different testing services, and because inequities in the distribution of services, coupled with limited transportation and scheduling constraints, posed critical barriers to testing (and vaccination) services. Exhibit III.2. summarizes these approaches. They are not mutually exclusive; some programs used them in combination. Many programs also bundled testing services with education and outreach intended to increase awareness and confidence in testing, although we did not find any testing programs whose sole approaches consisted of education or outreach (in the absence of testing services).

Exhibit III.2 Primary approaches of COVID-19 testing programs

Approach | Description
Increase access to COVID-19 testing
Mass testing clinics or events | Programs held large-scale testing clinics or events set up to provide a high volume of tests in one location. These could be drive-through or walk-up events and could be recurring or one-time events. If they were recurring, they usually had a consistent time and location.
Testing in health care settings | Programs delivered testing in health care settings, such as federally qualified health centers. These services were generally recurring, rather than one-time events.
Community testing clinics | Programs set up testing clinics in community spaces where people congregate. The clinics relied on existing infrastructure from the community sites. These services were generally recurring, rather than one-time events.
Mobile testing clinics | Programs deployed traveling vans or mobile units to convenient locations in the community, and individuals came to the mobile units to receive testing.
In-home testing | Mail-in testing programs enabled people to self-test. In addition, mobile teams provided COVID-19 testing in the recipients’ homes. Some organizations also distributed rapid tests (for later home use) at community events.

COVID-19 testing programs implemented several approaches to make testing convenient for communities.

- Mass testing clinics or events. Mass testing clinics were large in scale, functioning to provide a high volume of tests in a single location, such as a parking lot or other open space. Mass testing programs were mostly commonly administered by city, county, or state health departments. For example, the Utah Department of Public Health, in partnership with the Utah National Guard and Centers for Disease Control and Prevention, established a mass testing site in a vacant rodeo barn outside of Salt Lake City, Utah, providing tests to nearly 40,000 people from December 2020, through April 30, 2021 (Gillwald et al. 2022).
- Testing in health care settings. Federally qualified health centers (FQHCs) commonly provided testing for communities (Berner et al. 2022; Davis et al. 2020; Kim et al. 2021). Other examples of health care-based clinics included community health clinics (Barry et al. 2020) and rehabilitation centers for people experiencing homelessness (Berner et al. 2022). Testing clinics in health care settings sometimes integrated testing into clinical care and sometimes set up separate testing operations directly outside of the clinics. For example, La Clínica Esperanza, a community clinic in Providence, Rhode Island, set up a tent outside of the clinic where people could receive testing (Barry et al. 2020). Many health care-based clinics offered testing to people regardless of whether they were existing patients (Barry et al. 2020; Davis et al. 2020).
- Community testing clinics. Community testing clinics delivered testing at specific spaces in the community where people regularly congregate for work, education, worship, or other activities, as shown in the call-out box. Of the testing programs we reviewed, most such clinics were administered by local health departments, followed by academic institutions, often in partnership with local community-based organizations (CBOs). Testing services were typically recurring and integrated into existing operations at these locations. For example, in the Faithful Response to COVID-19 program, staff from the Kansas City, Missouri Health Department partnered with local faith-based organizations and church to integrate COVID-19 testing with church activities at a predominantly African American church in Kansas City (Berkley-Patton et al. 2022).
- Mobile testing clinics. Some programs deployed vans or trailers to provide testing at various locations around the community. In some cases, mobile testing units supported the community-based testing services described above, with mobile units parked outside of venues like churches and barber shops (Whanger et al. 2022, key informants). One key informant from a county health department described setting up vans at community events such as health fairs. In other cases, vans moved around communities and residential areas based on communities’ needs. For example, Atrium Health deployed mobile testing units to emerging COVID-19 hotspots in Charlotte, North Carolina, based on geographic information system data mapping COVID-19 incidence (Atrium Health 2020). In Section VI, we describe methods for identifying hotspots and communities at disproportionate risk of COVID-19 in more detail. Mobile testing programs were administered by academic institutions, CBOs, and hospitals or health systems, often working in partnership.
- In-home testing. In-home testing programs, commonly administered by academic institutions and state health departments, enabled patients to get tested for COVID-19 without leaving their homes. In most cases, this occurred through mail-in testing programs that provide test kits (generally rapid antigen tests) to qualifying households and included instructions for their use (Barrett et al. 2022; Illinois Department of Public Health 2022, the Rockefeller Foundation 2022; Singler et al. 2023; University of Utah 2022). For example, the NIH-administered Say Yes! Covid Test program mailed COVID-19 test kits to households, along with instructions for their use and post-testing guidance (Singler et al. 2023). While most in-home testing programs in our review operated by mail, we identified one program in the literature that deployed vans staffed with emergency medical service providers to the households of frail and older adults to administer in-home PCR testing (Goldberg et al. 2020). Similarly, a key informant’s academic institution used community health workers (promotoras) to visit and perform in-home testing for local residents who could not attend community testing clinics due to their age or health status. Several key informants’ organizations, often CBOs, distributed rapid antigen tests (for later home use) at community events where people were already congregating, such as community vaccination clinics.

Bringing testing to communities

Examples of community clinic locations:

- Churches
- Food pantries
- Homeless shelters
- Schools
- Workplaces

Examples of sites that mobile clinics visited:

- Airports and bus transfer stations
- Areas where farmworkers live and congregate
- Barber shop parking lots
- Church parking lots
- Homeless encampments
- Parks
- Roaming

Programs selected testing sites based on the needs of the populations they served. For example, mass testing sites often were established in communities with lower income, communities with high proportions of people of color, and communities with notable gaps in testing services (Hansotte et al. 2021; Gillwald et al. 2022). Beyond addressing resource sparsity, community-based and mobile testing clinics often selected locations based on convenience, with specific populations in mind. For example, several programs serving Black and Latinx populations selected churches as venues for community-based testing clinics, given the recognition of the central role that churches often play in these communities (Berkley-Patton et al. 2022; Bigelow et al. 2021; 2022; Jaklevic et al. 2021). An NIH-funded, academic-community partnership seeking to increase testing access among farmworkers in California planned to deploy mobile vans to areas where farmworkers regularly congregate (UC Davis Health 2020). Information on community needs and assets was often gained through collaboration and planning with CBOs that have knowledge of their communities, as discussed in Sections III.C.4 and VI.A.

### 2 Strategies to facilitate delivery of COVID-19 testing programs

COVID-19 testing programs used a variety of delivery strategies to enhance the effectiveness of the approaches described above. Exhibit III.3 and the following section presents these delivery strategies, organized according to whether they had the potential to achieve the following outcomes: (1) strategies to increase access to, awareness of, and confidence in COVID-19 testing; (2) strategies focused on increasing awareness of and confidence in COVID-19 testing; and (3) strategies used to increase access to testing. Within each of these categories, we present strategies organized by how commonly they appeared in the literature.

Exhibit III.3 Strategies to facilitate delivery of COVID-19 testing programs

Strategy | Examples
Increase access to, awareness of, and confidence in COVID-19 testing
Partner with established community organizations and trusted leaders to promote and deliver testing | - Partnerships with community-based organizations, such as nonprofits (Brown et al. 2021), food pantries (Barry et al. 2021), churches (Bigelow et al. 2021); - Trusted community leaders such as faith leaders (Berkley-Patton et al. 2022) and school staff (Chamie et al. 2021); - Community health workers (University of Utah 2022), including promotores/as (Degarmo et al. 2022)
Engage multilingual staff | - On-site interpreters (e.g., Degarmo et al. 2022)
Increase awareness of and confidence in COVID-19 testing
Develop population-specific or culturally tailored messaging to raise awareness about the importance of testing and available services | - Materials translated into multiple languages (Hansotte et al. 2021); - Religiously tailored messaging (Berkley-Patton et al. 2022)
Use multiple channels to increase reach of testing information | - Printed materials (Barry et al. 2020); - Radio and TV advertisements (Hansotte et al. 2021); - Social and digital media (Singler et al. 2023); - Phone calls and text messages (University of Utah 2022)
Prioritize patient experience, comfort, safety, and dignity | - Expedited testing process (Chamie et al. 2021); - Privacy screens (Neely et al. 2021); - Anonymized testing (Chidavaenzi et al. 2022)
Increase access to COVID-19 testing
Offer walk-up options and expand hours | - Evening and weekend hours (e.g., Chamie et al. 2022); - Testing offered during workplace shift changes (Chidavaenzi et al. 2022); - Walk-up options (e.g., Appa et al. 2021; Barry et al. 2020)
Address financial barriers to testing | - Free testing (Berkley-Patton et al. 2020); - Evening and weekend hours so recipients would not have to forego income (Chamie et al. 2022); - Financial resources to help people testing positive make up for lost income (Bigelow et al. 2021)
Reduce documentation requirements for testing | - No identification requirement (Hernandez et al. 2021); - No health insurance requirement (Atrium Health 2023); - No referral requirement (Degarmo et al. 2022)
Provide alternatives to online registration and tracking | - On-site registration (Hansotte et al. 2021); - Phone or text message follow-ups (Barry et al. 2020)
Other goals
Coordinate testing with other health and social services to meet health-related social needs | - Vaccination services (Chamie et al. 2022); - Food resources (Barry et al. 2020)

The most common delivery strategies in our review—partnering with established community organizations and leaders and engaging bilingual staff—helped programs increase testing access, awareness, and confidence at the same time.

- Partnerships with CBOs provided venues to expand testing access while drawing on their trusted status. Many programs involved collaborations between academic institutions, medical centers, or public health departments and established CBOs (Berkley-Patton et al. 2022; Hansotte et al. 2021; Brown et al. 2021). As described above, these partnerships enhanced access by providing testing venues in places like churches and schools (Degarmo et al. 2021; Hansotte et al. 2021). These partnerships increased awareness by promoting testing events through existing communication channels (Berkley-Patton et al. 2020). They also helped to foster testing confidence by building on CBOs’ longstanding relationships with the communities they serve (Hansotte et al. 2021; UC Davis Health 2020).
- Community leaders served as ambassadors to help increase awareness of and confidence in testing services (Barry et al. 2022; Berkley-Patton et al. 2022; Chamie et al. 2022). Church pastors (Berkley-Patton et al. 2022), school staff (Chamie et al. 2022), health care navigators (Barrett et al. 2022; DeGarmo et al. 2022), and other members of the community used their reach, influence, and cultural competency to dispel misinformation, emphasize the importance of testing, and promote testing services. In some cases, these community partners also helped administer testing. For example, an NIH-funded central California mass testing program, run through a community-academic partnership, engaged the school superintendent—described as a trusted community leader—to administer tests to Latinx residents (Chamie et al. 2022). Community leaders also volunteered to support testing programs, by acting as greeters and directing traffic (Appa et al. 2021; Hernandez et al. 2021), or conducting follow-up calls with those testing positive (Barry et al. 2020).
- Engaging bilingual staff increased access and confidence among non-English speakers. A key informant from an academic institution noted that promotoras publicized testing events on social media and by word of mouth, in English and Spanish. Many programs in our literature review similarly engaged Spanish-language interpreters (Chamie et al. 2022; Gillwald et al. 2022), while several also provided interpreters for other languages, including Vietnamese (Hernandez et al. 2021) and Indigenous-Mayan language (DeGarmo et al. 2022). By making information accessible to people who did not speak English, this strategy addressed a key language access barrier. In addition to increasing access, the presence of bilingual staff on-site may have also fostered trust and confidence among non-English speaking communities (Degarmo et al. 2022).

Program spotlight: Partnering with African American churches

In the Faithful Response to COVID-19 program, the Kansas City Health Department partnered with local faith-based organizations to deliver testing to African American churchgoers (Berkley-Patton et al. 2022). Eight participating churches increased access by providing convenient venues for testing services, which were often scheduled to align with church programming. They disseminated information through church bulletins to raise awareness. Partnering with churches also gave programs access to pastors who were trusted and respected by many in the community. Church pastors used their influence to communicate the importance of testing to church attendees. They also role-modeled the process of being tested from the pulpit during church services, which may have increased confidence among churchgoers.

Thoughtfully designed communication strategies and efforts to ensure positive testing experiences further increased awareness of and confidence in testing.

- Programs used clear, accessible, and culturally tailored messaging to raise awareness about the importance of testing, address misinformation, and promote specific testing services. These outreach strategies often involved a combination of educational content about the importance of testing and promotion of specific testing services (Barry et al. 2020; Davis et al. 2020; Whanger et al. 2022). Given that many people were unaware of COVID-19 policies, such as free testing made possible by the CARES Act, it was important for programs to communicate that testing was offered free of charge. It was also important that programs ensure promotional messaging was accessible for diverse communities. One program, run by an academic medical center in partnership with rural FQHCs, developed information at a 6th-grade reading level (Davis et al. 2022), and many programs translated communications into multiple languages, including English, Burmese, Spanish, and Vietnamese (Hansotte et al. 2021; Hernandez et al. 2021). Messaging was sometimes culturally tailored to specific communities. For example, the Faithful Response program developed religiously tailored messages about the importance of testing for African American church attendees (Berkley-Patton et al. 2022). In the Oregon Saludable: Juntos Podemos (Healthy Oregon: Together We Can) program, academic and community partners engaged Spanish-speaking promotoras to conduct outreach to Latinx communities to address misinformation and promote testing services; their communications drew on Latinx cultural values, such as collective welfare (DeGarmo et al. 2022).
- Disseminating information through a range of channels helped programs expand reach to different communities and raise awareness about testing. Digital platforms included social media (Jaklevic et al. 2021; Singler et al. 2023) and local health department websites (Barry et al. 2020; Whanger et al. 2022). Some programs used TV and radio advertising to promote testing, often with an emphasis on reaching specific populations like Spanish-speakers (Chamie et al. 2022; DeGarmo et al. 2022). Some programs distributed printed materials like pamphlets and flyers around the community (Hansotte et al. 2021; Davis et al. 2022). Other programs used in-person strategies such as door-to-door campaigning (Hansotte et al. 2021) or promoting in high-traffic areas like grocery stores, church services, schools, and workplaces (DeGarmoet al. 2022). In many cases, staff and volunteers made phone calls or sent text messages to inform people of testing services and remind them about upcoming appointments (University of Utah 2022). Many programs used multiple strategies to expand their reach (Hansotte et al. 2021; DeGarmo et al. 2022; Singler et al. 2023).
- Programs prioritized patient experience, comfort, privacy, and dignity throughout the testing process. Efforts to maximize patient comfort and create a positive testing experience included expediting testing procedures (Chamie et al. 2022; McCollum et al. 2022); staffing on-site greeters to welcome patients and answer questions (Appa et al. 2021; Gillwald et al. 2022), creating a clean and welcoming testing space, and offering hygiene kits and snacks (Davis et al. 2020; Winterbauer et al. 2021). Several programs took measures to increase patient privacy and dignity, including anonymizing the testing process (Chamie et al. 2022; Chidavaenzi et al. 2022), erecting privacy screens (Neely et al. 2021), and using saliva testing kits, which are less invasive than to nasal swabs (Key informant). In a collaboration between several universities, an academic medical center, and the Chicago Department of Public health, nursing student volunteers allowed patients to collect their own samples (Neely et al. 2021). Self-sampling was described as a way to give patients control over their own bodies and build trust among communities who have been traumatized (Neely et al. 2021). These strategies are important because medical racism and stigma have undermined patient trust and decreased confidence in testing (Neely et al. 2021; Corneli et al. 2022; DeGarmo et al. 2022).

Program spotlight: Using multiple dissemination channels to provide education and raise awareness about testing

Drawing on principles of social marketing, the federal Say Yes! COVID Test program used a combination of website, digital advertising, social media, and paid media to encourage the use of home testing among historically marginalized communities (Singler et al. 2023). The NIH-administered program emphasized the importance of engaging local partner organizations and leaders to act as spokespeople and share personal experiences with testing. It also translated all promotional material into English and Spanish to broaden reach.

Programs took measures to further enhance access to testing, beyond the primary approaches to increase geographic access described above.

- Offering walk-up testing and expanded hours helped to increase access to testing for people without cars or with restrictive work schedules. For example, an academic-community partnership bringing testing services to two predominantly Latinx counties in California selected walk-up testing sites in central, well-known locations that people could easily access on-foot, including a park and a community center (Chamie et al. 2022). Many of the mass testing events, while designed for drivethrough operations, also offered walk-up options for those without vehicles (Appa et al. 2021; Hansotte et al. 2021). To accommodate workers facing scheduling constraints, programs offered testing services outside of typical business hours (Chamie et al. 2022; Gillwald et al. 2022).
- Programs increased financial accessibility by lessening the economic burden associated with going to get tested or receiving a positive test result. Under the CARES Act, insurance carriers were required to cover COVID-19 testing without cost sharing, and programs were funded to provide free testing to people who were uninsured (Coronavirus Aid, Relief, and Economic Security Act 2020). However, lost wages associated with testing still posed a barrier to testing for many people. Programs that offered testing outside of standard working hours not only increased accessibility for workers but also helped to ensure recipients would not forego income when seeking testing (Chamie et al. 2022; Gillwald et al. 2022). Some testing programs also connected people who tested positive to financial resources to help them make up for lost income while they isolated (Bigelow et al. 2021; Chamie et al. 2022).
- Reducing or eliminating requirements for documentation or referrals further increased accessibility. Many programs eliminated requirements for physician referral or health insurance (Davis et al. 2020; Degarmo et al. 2022). This ensured that anyone could access testing, regardless of prior access to or engagement with the health care system. Some programs, particularly those serving Latinx and immigrant communities, did not require identification to be tested, thereby mitigating concerns about deportation among those who were undocumented (Chamie et al. 2022; Hernandez et al. 2021).
- Programs ensured those without internet or digital literacy could access testing appointments and test results. Many testing programs offered on-site registration for those without internet access or with less familiarity of online systems (Gillwald et al. 2022; Hansotte et al. 2022). In some cases, program staff or volunteers called or texted patients to deliver test results instead of requiring them to log onto an online system (Barry et al. 2020; Chamie et al. 2022). Similarly, a key informant from a tribal health system described implementing a patient portal with an SMS system, which allowed patients to receive their COVID-19 test results via text message without having to use the internet. Follow-up calls and texts also presented an opportunity for staff to provide information to patients, including isolation guidance and COVID-19 treatment options for those testing positive (Barry et al. 2020; Chamie et al. 2022; DeGarmo et al. 2022; Gillwald et al. 2022).

Key informant spotlight: Using community health workers to deliver test results

An academic organization offering testing services in different communities throughout a state noted that having to check test results online was a barrier for its populations of focus. To overcome this, community health workers called program recipients who had not checked their online results within 48 hours to ask for permission to share their results via phone instead.

Some programs began with COVID-19 testing and then recognized an opportunity to support people’s health and social needs more broadly.

- Some testing programs addressed health care needs by bundling services or providing referrals. For example, a community testing program in California adapted their testing site to double as a vaccination clinic and also began linking patients with mental health services (Chamie et al. 2022). A qualitative review of best practices for providing community testing to vulnerable populations described a mobile testing service that doubled as a portable clinic, offering blood pressure and HIV screenings and referrals to primary care providers in their community (Winterbauer et al. 2021).
- Other programs addressed health-related social needs. For example, testing programs provided referrals to child care, hotels, food vouchers, and financial resources (Barry et al. 2020; Bigelow et al. 2021; Winterbauer et al. 2021). Similarly, a key informant at a local health department described coordinating testing with the provision of hot meals, groceries, and care packages. Another key informant from a CBO, operating at the county level, noted that such strategies not only enhance access to services but also build the community’s trust in the organization sponsoring the testing program.

Key informant spotlight: Meeting community needs

A local health department worked with the U.S. Department of Housing and Urban Development to set up testing and vaccination sites at housing facilities for senior citizens. They also used these sites to provide hot meals, groceries, care packages, mental health assessments, and follow-up check-ins for senior residents.

### 3 Challenges to COVID-19 testing program implementation

Both the literature and key informants described implementation challenges related to resources, operational inefficiencies, and partnerships. These challenges applied across different testing approaches. In this section, we describe common challenges to implementation that presented across different testing approaches. In the next section, we describe strategies that staff used to overcome those challenges.

Exhibit III.4 Implementation challenges and strategies of COVID-19 testing programs

Category | Challenges staff faced in program implementation | Strategies staff used to facilitate program implementation
Resources | Budget and funding constraints, staffing limitations, and issues with obtaining and storing supplies posed a challenge to program implementation. | Diverse staffing and donated supplies provided programs with needed resources.; Logistical efficiencies also helped staff make use of scarce resources.
Operations and logistics | Issues with patient tracking, staff communication, and staff driving time decreased efficiency of program operations. | Integrating testing into existing institutional infrastructure and processes; developing traffic management and other logistical efficiencies; and implementing systems for staff communication and coordination helped to facilitate smooth program delivery while making use of scarce resources.
Community partnerships | Some programs faced challenges related to buy-in and trust when engaging with community partners. | Early and frequent communication with community partners helped gain community buy-in.

Resource limitations—including constraints on budget, staffing, and supplies—were among the most cited challenges to implementation among the testing programs we reviewed.

- Issues with obtaining, storing, and transporting testing supplies were among the most common challenges staff faced. Several programs noted a shortage of supplies early in the pandemic, such as test kits and personal protective equipment for staff (Appa et al. 2021; Jaklevic et al. 2021; Molling et al. 2020; Whanger et al. 2022). For example, a city-level mobile testing program run by a Black physicians’ group in partnership with the Philadelphia Department of Public Health noted that it was difficult to obtain testing kits early in the pandemic (Jaklevic et al. 2021). Programs also faced challenges with storing and transporting supplies, including test samples (Appa et al. 2021) and privacy screens (Neely et al. 2021). For example, a university-administered, city-level mass testing clinic in Bolinas, California noted that some of their samples leaked on transport (Appa et al. 2021).
- More broadly, some programs described constraints related to the cost of providing testing and restrictions placed on them by funders. Testing events were associated with numerous costs, including staff time, community mobilization, laboratory testing costs, and government support for people testing positive (Chamie et al. 2022). A source describing a partnership between a local CBO, the West Virginia Department of Health and Human Services, and the West Virginia National Guard to advance testing in West Virginia reported budgetary constraints for rural clinics related to obtaining and transporting supplies (Whanger et al. 2022). Programs also faced challenges related to funding requirements. For example, a key informant from an academic institution explained how restrictions on grant funds limited their options in implementing testing programs in coordination with vaccination services.
- Staff availability and capacity were also challenges for testing programs. For example, Whanger et al. (2022) conducted focus groups with rural clinic staff in West Virginia, who noted a strain on staff time needed to provide testing in addition to basic care. A program in which the National Guard partnered with local public health agencies to deliver mass testing to rural communities in West Virginia held events that were often scheduled with only 24 hours of lead time, which did not give them adequate time to find and onboard staff and volunteers (Dumproff et al. 2022).

Some testing programs also experienced logistical issues related to patient tracking and staff communication and transportation.

- Some programs faced challenges with patient registration and tracking. For example, a mass clinic in rural Wisconsin described challenges faced by staff when registering and following up with patients who did not have a preexisting relationship with the health system (Molling et al. 2020). This was because these patients did not have screening data available for registration and they did not have employer information available for sending return-to-work instructions (Molling et al. 2020). As described above, on-site registration was helpful for people without access to the internet; however, it posed challenges to implementation if hand-written labels were difficult for staff to read (Appa et al. 2021).
- Challenges with staff communication and transportation reduced program efficiencies. Program staff sometimes struggled to communicate about test results and participant information, particularly at the larger testing sites where they were stationed at a distance from one another (Gillwald et al. 2020) or when all parties were wearing masks (Appa et al. 2021). These communication issues made testing operations slower and less efficient. Programs noted additional inefficiencies related to staff transportation (Goldberg et al. 2020; Whanger et al. 2022). For example, health care workers faced long and inefficient driving routes to see only a few patients when traveling to older adults’ homes to administer tests as a part of a state-level program run by a hospital system in partnership with the state department of public health (Goldberg et al. 2020).

Programs involving health care–community collaborations described challenges around obtaining buy-in from potential community partners. For example, a key informant representing an academic institution described challenges collaborating with potential testing venues. While the organization identified grocery store parking lots as convenient testing venues, the grocery stores objected to being associated with a COVID-19 testing events and having potentially ill people congregate in their parking lots, fearing these activities would drive away customers. The informant’s organization ended up moving its testing sites to community locations, such as parks, instead. One study from the peer-reviewed literature described a state-level trial in which community sites were randomly assigned to receive information about testing from promotores versus standard outreach protocols (DeGarmo et al. 2022). Authors noted that some community partners initially objected to the mode of outreach being randomized, but they eventually were supportive after trust between the researchers and community was established.

### 4 Strategies to facilitate COVID-19 testing program implementation

In this section, we elaborate on the third column of Exhibit III.4 to describe the strategies that staff, volunteers, and partners used to overcome common challenges and successfully implement testing programs.

Programs maximized scarce resources through creative staffing and donated supplies.

- At a time when health care staff were overburdened, diverse clinical and nonclinical staff and volunteers worked together to implement COVID-19 testing programs. In addition to health care providers (Davis et al. 2020; McCollum et al. 2022), staff and volunteers included medical students (Neely et al. 2021), community health workers (Barrett et al. 2022; Barry et al. 2020; DeGarmo et al. 2022), church leaders (Berkley-Patton at al. 2022), and teachers (Chamie et al. 2022), among others. Engaging nonclinical staff helped to manage the workload and unburden clinical staff (Chidavaenzi et al. 2022; Whanger et al. 2022). By coordinating with CBOs, programs had access to robust networks of motivated volunteers to help promote, facilitate, and deliver testing services (Appa et al. 2021; Berkley-Patton et al. 2022; Chamie et al. 2022). In some cases, existing professional teams pivoted their services to support testing efforts. Examples include paramedics administering in-home testing to homebound residents (Goldberg et al. 2020), a mobile mammography clinic delivering COVID-19 testing in rural Louisiana, and the West Virginia National Guard helping to coordinate mass testing events (Dumproff et al. 2022).
- Programs facing supply shortages benefited from donations from the government and partners. A surgeon in Philadelphia drew on her professional network to gather free COVID-19 tests for use by a small, city-level community testing clinic (Jaklevic et al. 2021). Several key informants from CBOs and health systems received at-home test kits for free through their state or county health departments, allowing them to spend grant funding on other needs, such as outreach and building staff capacity.

Key informant spotlight: Partnering with test manufacturers and a pharmaceutical company

- A foundation worked with COVID-19 test manufacturers to ensure a steady supply of tests throughout the country. The foundation also invested in a public–private partnership between one test manufacturer, state health departments, and a global logistics and distribution provider to ensure widespread access to at-home COVID-19 tests in five states.
- A local health department was approached early in the pandemic by a pharmaceutical company headquartered in its area, which offered to provide free testing services to frontline workers, including grocery store and day care workers.

Operational efficiencies helped staff to deliver services while making use of scarce resources.

- Integrating testing services into host venues’ existing infrastructure and systems took advantage of community assets and helped staff deliver services efficiently. Churches, schools, and other community-based testing venues provided needed infrastructure, such as electricity, computers, refrigeration, and gathering and waiting areas (Berkley-Patton et al. 2022; Molling et al. 2020; Neely et al. 2021). Programs increased the efficiency of staff efforts by delivering testing to coincide with host institutions’ schedules, such as delivering testing during scheduled church programming (Berkley-Patton et al. 2022) or workplace shift changes (Chidavaenzi et al. 2022; see program spotlight). These integrations also helped to improve access and confidence among program recipients.
- Program staff developed various systems to improve program operations. For mass testing clinics, which served hundreds and sometimes thousands of people daily, traffic management was critical to success (Dumproff et al. 2022; Gillwald et al. 2022; Hernandez et al. 2021). Several articles about larger testing clinics made a point to describe their traffic and site layouts (Appa et al. 2021; Molling et al. 2020). Designating personnel to direct traffic, greet patients, and provide additional logistical supports improved flow during testing events (Appa et al. 2021; Hernandez et al. 2021; Whanger et al. 2021). Similarly, a program administering in-home testing to homebound residents decided to cluster home visits to increase driving efficiency (Goldberg et al. 2020). Program staff also made improvements to internal communication (Gillwald et al. 2022; Molling et al. 2020). For example, one mass testing program, run by state and county health departments, faced challenges to communications between staff. The program responded to this challenge by using a Google spreadsheet so staff could track and communicate patient results in real time (Gillwald et al. 2022).

Program spotlight: Integrating testing into the workplace

A program seeking to increase COVID-19 testing among members of the San Carlos Apache Tribe in southeastern Arizona implemented serial testing at a detention center and casino locations (Chidavaenzi et al. 2022). Staff from the tribe’s Department of Health and Human Services, with support from the CDC, conducted testing in different physical spaces within each venue, such as in detention center pods. They also conducted testing to align with workplace scheduling, including late nights and early mornings when casino employees changed shifts. Adapting testing protocols to the specific workplace buildings and employee schedules likely helped increase efficiencies for program staff while also enhancing accessibility and ultimately uptake among people being tested.

Regular planning meetings were important for building strong community partnerships and designing effective services. Partnerships between two or more organizations, including academic institutions, health departments, health systems, and local CBOs were nearly universal among the testing programs in our scan. Programs involving such collaborations described the importance of holding regular meetings for all partners to communicate and learn from each other throughout program planning and implementation (Berkeley-Patton et al. 2022, Davis et al. 2020; DeGarmo et al. 2022; Molling et al. 2020). CBOs have built robust and trusted relationships with communities, allowing them to offer insight into residents’ needs, and what kinds of intervention strategies would be most resonant and effective (Office of Minority Health 2020, UC Davis Health 2020). For example, a university-administered program to bring mobile testing to farmworker communities in California’s central valley gained insights from community partners who had longstanding relationships with farmworkers and could offer recommendations for convenient testing locations (UC Davis Health 2020).

Key informant spotlight: Adapting reporting requirements to communities

Recognizing that some tribal communities have a historically informed distrust of reporting information to the federal government, a federal funder did not want significant reporting requirements to discourage these entities from applying for a federal grant. The agency purposefully required less reporting on outcomes than is typically required to make its COVID-19 grant accessible to tribal entities that had not previously received federal funding.