# II Populations of focus for COVID-19 testing and vaccination and routine vaccination programs

In this section, we first summarize the evidence on populations that are medically or socially at disproportionate risk of COVID-19 or related adverse outcomes. This definition of the population of focus for the environmental scan encompasses groups with medical conditions that increase their risk of infection and adverse outcomes, groups facing greater risk of COVID-19 infection because of where they live and work where they live and work, and groups facing barriers to health services. Drawing on equity concepts, we then review barriers to COVID-19 testing and vaccination awareness, confidence, access, and uptake. Finally, we provide a high-level summary of how programs sought to address these barriers and how they have defined and prioritized communities facing barriers.

## A Summary of populations at disproportionate risk of COVID-19 and adverse outcomes

People and communities may experience disproportionate risk of COVID-19 due to medical factors, social factors, or both (Au Young et al. 2022; CDC 2020e, 2022a, 2022h). People who are immunocompromised face higher risks of contracting COVID-19 and those with chronic conditions have increased risk of adverse outcomes from infection. Social factors such as living conditions or barriers to care can increase both the risk of COVID-19 exposure and adverse outcomes. These factors often intersect and compound to amplify risk. For example, structural inequities affecting some racial and ethnic groups have resulted in over-representation in essential service jobs and higher risk of COVID-19 exposure, high rates of medical conditions that increase risk of adverse COVID-19 outcomes, and low access to medical care.

Below we summarize the disproportionate impacts of COVID-19 exposure, hospitalization, and death on various communities, including older adults, people with comorbidities, specific racial and ethnic groups, people in rural areas, people who are incarcerated, people experiencing homelessness, people residing in long-term care facilities, people with disabilities, and people who are uninsured. We further describe the inequities and barriers contributing to greater risk of COVID-19 and adverse outcomes for these groups in Section 11.B.

Older adults and people with multiple conditions are at highest risk of hospitalization and death from COVID-19. Adults ages 65 and older have had the highest rates of death from COVID-19 throughout the pandemic. Those ages 85 and older have had especially high mortality: in April 2023, the COVID-19 death rate for adults over 85 was 350 times higher than for people ages 18–29 and, as of September 2022, adults over 85 made up about 40 percent of deaths in the U.S. from COVID-19 (CDC 2023d, 2022h). Having medical conditions such as asthma, cancer, HIV, chronic liver or lung diseases, or diabetes increases the risk of death and complications from COVID-19 (CDC 2023f). As people age, their risk of some chronic conditions increases, compounding their risk of adverse outcomes. People with substance use disorder also have a higher prevalence of chronic conditions, such as kidney, liver, and lung diseases, and hence a higher risk of death and hospitalization from COVID-19 (Wang et al. 2021; Baillargeon et al. 2021).

Multiple racial and ethnic groups including Black, Hispanic or Latinx, American Indian/Alaska Native people, and Native Hawaiian or other Pacific Islanders have experienced higher age-adjusted rates of COVID-19 cases and deaths than non-Hispanic white people. Disparities in COVID-19 cases and mortality by race and ethnicity have changed at different points in the pandemic, generally widening as the virus surged (Ndugga et al. 2022). In 2021, Pacific Islanders, Hispanic or Latinx people, Black people, and American Indian/Alaska Native people had death rates that were double those of non-Hispanic white and Asian Americans (CDC 2021f). Black and Hispanic people had the highest mortality rates during the first few months of the pandemic, but for most of the pandemic, American Indian or Alaska Native people have experienced the highest mortality rates (CDC 2022h). Some gaps in testing and vaccination narrowed over time, particularly as vaccination and testing programs focused on reducing inequities and increasing vaccine confidence (Rubin-Miller et al. 2020; Anderson et al. 2021; Kriss et al. 2022; CDC 2021e). For example, disparities in rates of vaccination between Black and non-Hispanic white populations have narrowed from a 14-percentage point difference in April 2021 to a difference of 8 points in November 2021 (Burki 2021; Kriss et al. 2022). As of July 2021, vaccination rates among American Indian and Alaska Native people changed from being among the lowest by race and ethnicity to the highest (Kriss et al. 2022; Bennett 2021). Disparities in death rates by race and ethnicity have also decreased over time but still persist (CDC 2022h).

People in rural areas have faced higher risk for COVID-19 infection and death in the later phases of the pandemic. Initially, in early 2020, COVID-19 infections were highest in urban areas. However, in late 2020 rural areas began to experience higher rates of infection and death, and the urban–rural disparity in COVID-19 morbidity and mortality has increased throughout the pandemic (Cuadros et al. 2021; Saelee et al. 2022). Testing and vaccination barriers such as provider shortages, distance to test or vaccination sites, and lower levels of vaccine confidence among rural populations compared to urban populations have contributed to these disparities (Saelee et al. 2022; Tan et al. 2020).

COVID-19 death rates are also higher for people who are incarcerated, are experiencing homelessness, or reside in a long-term care facility. In addition to geographic location, living situations also put people at increased risk for COVID-19. For example, in 2020, people who were incarcerated had infection rates 5.5 times higher than the general population and death rates that were three times higher (Saloner et al. 2020). While these disparities began to decline in early 2021, cumulative COVID-19 case and mortality rates are substantially higher among the incarcerated population compared to the general population (Marquez et al., 2021b). People experiencing homelessness often reside in congregate settings, such as encampments and shelters, and have less access to prevention measures and health care. One 2021 study found that the COVID-19 mortality rate was 1.3 times higher for people experiencing homelessness than the general population (Leifheit et al. 2021). Residents in long-term care facilities, while less likely to be infected with COVID-19, had high mortality rates, particularly before the COVID-19 vaccination was available. In March 2021, about 8 percent of people in long-term care facilities had died of COVID-19 (The Covid Tracking Project 2021). However, after the introduction of the vaccine, mortality rates dropped steeply in most states (Chidambaram et al. 2021).

People with disabilities and people who are uninsured also have experienced increased risk for COVID-19 and adverse outcomes. For example, a 2022 study demonstrated that people with a physical or intellectual disability are less likely to be vaccinated than those without a disability, despite having more vaccine confidence (Ryerson et al. 2022). While research on the impact of COVID-19 for people with disabilities is limited (Lebrasseur et al. 2021), research demonstrates that individuals with intellectual disabilities are at increased risk of death (Gleason et al. 2021). One 2020 study cited morality rates eight times higher than the general population (Landes et al. 2020). People who are uninsured are also at increased risk of adverse outcomes from COVID-19, despite having access to free testing and vaccination. For example, fear of co-pays and costs of treatment after receiving a positive test, contributes to delayed care and higher rates of COVID-19 hospitalization and mortality (Wafsy 2023; Gaffney et al. 2022; Miller et al. 2021). In addition, while federal legislation requires insurers to cover the costs of COVID-19 tests and provided funding for free tests for uninsured people, some providers nevertheless charge patients for tests, contributing to confusion and concerns around costs (Gaffney et al. 2022).

## B Barriers to COVID-19 testing, COVID-19 vaccination, and routine vaccination

Multiple health equity frameworks recognize that inequities in structures, policies, and systems influence environments, living conditions, resources, and service delivery, posing barriers to health (Hacker et al. 2022; WHO 2010; O’Neil and Wesley 2021). These structural and social inequities cause barriers to COVID-19 testing and vaccination and routine vaccination services through several causal pathways, affecting confidence in and awareness of testing and vaccination services, access to those services, and ultimately use of testing and vaccines. Although other sources categorize barriers to COVID-19 vaccination in different ways—such as structural, behavioral, and informational barriers (CDC 2022l), or structural and attitude-related barriers (Gonzalez et al. 2021)—we organize findings on barriers according to our research questions, focusing on awareness, confidence, and access, which drive testing and vaccination uptake. We discuss additional barriers to routine vaccinations during the pandemic in Section V.

### 1 Barriers to awareness and confidence

Misinformation, low health literacy, digital divides, and language barriers limited awareness about testing and vaccination guidelines and available resources. Misinformation and limited information about current guidelines and available vaccination and testing resources dissuade people from seeking testing (Alcendor et al. 2021; Corneli et al. 2022; Hernandez et al. 2021). For example, one testing program serving a low-income, majority Hispanic community in Northern California described a common misconception that people needed to be symptomatic to be tested or that testing was not necessary post-vaccination (Chamie et al. 2022). Low health literacy and digital divides made it difficult for some people to research available resources and register online for vaccination and testing appointments (Hansotte et al. 2021; Abdul-Mutakabbir et al. 2021; Public Health—Seattle and King County 2021). Many programs also noted language as a critical barrier to engaging with testing and vaccination resources, particularly among Latinx communities (Bigelow et al. 2021; Degarmo et al. 2022); one article we reviewed also noted language as a barrier for the San Carlos Apache Tribe accessing vaccination information (Le-Morawa et al. 2022).

Distrust in the health care system diminished confidence in COVID-19 testing and vaccination. Communities of color, Indigenous communities, immigrants, people with disabilities, and people with low levels of income and education have faced exploitation and discrimination within the U.S. health care system (AuYoung et al. 2022; Jaklevic et al. 2021). Given this legacy, some members of these communities have had lower levels of confidence in health care providers and health care organizations and were therefore hesitant to engage with testing and vaccination programs (Alcendor et al. 2022b; Boyd et al. 2022; Evans et al. 2021; CDC 2020e; DeGarmo et al. 2022; Neely et al. 2021). For example, in describing their intervention to improve the COVID-19 testing experience and build trust among those living in congregate settings—many of whom were people of color—Neely and colleagues (2021) emphasized how the present-day trauma of the COVID-19 pandemic for these communities compounded the historical trauma of medical racism (for example, in the Tuskegee Syphilis study), necessitating trauma-informed approaches to service delivery.

### 2 Barriers to access

Structural inequities in the allocation of health care resources resulted in geographic barriers to testing and vaccination services. For example, rural communities (McCollum et al. 2022; Kepka et al. 2021; CDC 2020e), tribal communities (Le-Morawa et al. 2022; Sears et al. 2023), and farmworker communities (UC Davis Health 2020) have been underserved by health care resources. Within urban areas, inequities in the spatial distribution of resources have resulted in health care “deserts” for lower-income communities and communities of color (Alcendor et al. 2022a; Neely et al. 2021; Servick 2020). An analysis of travel time to COVID-19 testing sites found that testing sites were more likely to be located at a farther travel distance from rural communities and communities with a higher percentage of racial and ethnic minorities and people who are uninsured (CDC 2020e).

Lack of reliable transportation and employment conditions are social determinants of health that compounded geographic access problems. For people who do not own vehicles, transportation poses a critical barrier to accessing vaccination and testing services, especially when those services are far away (AuYoung et al. 2022; Ella 2020; Hansotte et al. 2021; Kaiser Family Foundation 2021; Bigelow et al. 2021; Marquez et al. 2021a). Likewise, restrictive work schedules for essential workers and low-wage workers made it difficult to miss work for COVID-19 testing or vaccination appointments (Abdul-Mutakabbir et al. 2022; Jaklevic et al. 2021; Chamie et al. 2022).

Financial, health care, and legal concerns created barriers to testing and vaccination services. For people with low income (Gupta et al. 2022; Relias Media 2021; Hernandez et al. 2021) or who are uninsured (Barry et al. 2020; Budhwani et al. 2023), accessing testing and vaccination services may be financially out of reach. Out-of-pocket costs, lost wages for appointments or a positive test result, or a combination of these factors can impede access (Chamie et al. 2022; Gupta et al. 2022; Rockefeller Foundation 2022; Servick 2020). Moreover, those without a primary care provider may struggle to access testing and vaccination services without a physician referral (Degarmo et al. 2022; Jaklevic et al. 2021). People who are undocumented may face additional barriers to vaccination and testing, including not having a government-issued identification card or fear of deportation (Bigelow et al. 2021, 2022; Hernandez et al. 2021; Winterbauer et al. 2021; Buro et al. 2022; Demeke et al. 2022a; Demeke et al. 2022b). Despite federal legislation and guidance requiring free testing and vaccination with minimal documentation, identification, and referral requirements, people may still be confused by or unaware of these policies (Demeke et al. 2022a; Demeke et al. 2022b).

## C Populations prioritized by programs reviewed in this environmental scan

Programs included in the environmental scan and key informant interviews worked to deliver services to populations that were at disproportionate risk for COVID-19 or adverse outcomes based on the social and medical factors described in Section II.A and those facing barriers to testing and vaccination access, confidence, and awareness, described in Section II.B. The communities served by the programs we reviewed aligned closely with CDC’s guidance for prioritizing the selection of communities for vaccination interventions (CDC 2021f). In Section VI, we provide details on the data and information that programs used to identify priority populations.

Communities and people with lower access to health care resources were the broad focus of most programs, which aimed to directly deliver interventions to communities. At the community level, many programs worked to deliver testing and vaccination services in rural areas (Appa et al. 2021; Beste et al. 2021; Centene Corporation 2020; Dumproff et al. 2022; Molling et al. 2020) or urban neighborhoods with gaps in health care resources (AuYoung et al. 2022; Gupta et al. 2022; Jaklevic et al. 2021; Baker et al. 2021). At the individual level, many programs sought to provide testing and vaccination services to people who did not have health insurance (Barry et al. 2020; Gillwald et al. 2022; Winterbauer et al. 2021).

People deemed high-risk for COVID-19 due to specific conditions or illnesses were the focus of some programs. This included those living with HIV, people with substance use disorders, frail or older persons, pregnant persons, and those living with chronic disease (Harvard T.H. Chan School of Public Health 2020; Kim et al. 2021; Marcell et al. 2022; Washington et al. 2022; Whanger et al. 2022; Winterbauer et al. 2021).

Communities of color, such as Black, Hispanic or Latinx, and Indigenous communities impacted by the effects of structural racism were the priority for many programs. For example, the Black Doctors COVID-19 Consortium, in partnership with the Philadelphia Department of Public Health, offered church-based and mobile testing to Black residents in Philadelphia, Pennsylvania (Jaklevic et al. 2021). In a program run by the Indian Health Service, pharmacists delivered vaccination services to Indigenous communities living on Indian reservations in Oklahoma, Minnesota, Wisconsin, Michigan, Arizona, and Illinois (Gregory et al. 2021). The Clínica Esperanza/Hope Clinic hosted community testing events for Hispanic/Latino communities in Providence, Rhode Island (Barry et al. 2020). Many programs serving communities of color noted distrust of the health care system due to historical and ongoing discrimination as a barrier to intervention uptake (Evans et al. 2021; CDC 2020e; Degarmo et al. 2022; Neely et al. 2021).

People in specific occupational or residential settings with increased levels of COVID-19 transmission were the focus of some programs. For example, a California program planned to deploy vans to deliver testing to farmworkers and their families (UC Davis Health 2020). Many farmworkers did not have access to personal protective equipment and could not stay six feet apart due to the nature of their work. A similar vaccination campaign sent vans to rural areas across three states to deliver vaccination services (Relias Media 2021). Other programs set up temporary clinics in congregate settings to serve those living and working there, including homeless shelters (Berner et al. 2022), public housing (Alcendor et al. 2022a), detention centers (Chidavaenzi et al. 2022), and nursing homes (Alcendor et al. 2022a), among other spaces (Neely et al 2021).

Populations served by these programs are not mutually exclusive. Because of structural racism, people who are Black, Indigenous, Latinx, and from other communities of color are more likely to be essential workers, incarcerated, experiencing homelessness, or living with a chronic health condition (AuYoung et al. 2022; Boyd and Buchwald 2022; Hernandez et al. 2021; National Governors Association 2020; Servick 2020). Social and health resources are also less likely to be allocated to these communities (AuYoung et al. 2022). Many programs recognized these compounding risk factors, leading them to define their populations of focus at the intersections of race and ethnicity and poverty (Chamie et al. 2022; Baker et al. 2021) or occupation (NYU Silver School of Social Work 2022; Feifer et al. 2021).