# I Introduction

## A Motivation for the study and statement of the problem

The COVID-19 pandemic has exacerbated longstanding health inequities (Simmons et al. 2021). Historically marginalized, systematically under-resourced, and medically underserved U.S. communities have disproportionately experienced more COVID-19-related infections, hospitalizations, and deaths, compounded by limited access to vaccines and other effective mitigation strategies (Khanijahani et al. 2021; Smith et al. 2021; Romano et al. 2021; Webb-Hooper et al. 2020; Islam et al. 2021; Nayak et al. 2020). The evolving nature of COVID-19 guidance and the inconsistent approach to testing and vaccination across jurisdictions in the U.S. delayed shared learnings and rapid implementation of effective strategies for all communities (DeSalvo et al. 2021). Contextual factors such as social and cultural beliefs and norms presented additional challenges to COVID-19 testing and vaccine uptake in many communities once tests and vaccines were available (Reitsma et al. 2021; Nguyen et al. 2022). Further, rates of routine child and adult vaccinations fell during the pandemic in these already hard-hit communities, hampering efforts to eliminate existing inequities in routine vaccination coverage (CDC 2023b; Jain et al. 2022; Skolnik et al. 2021).

COVID-19 not only exacerbated longstanding inequities, but also exposed the structural factors underlying them (Isasi et al. 2021). Structural racism—defined as public and private policies, norms, and cultural representations that lead to unequal freedom, opportunity, value, resources, advantage, restrictions, constraints or disadvantage for individuals and populations according to their race or ethnicity (Braveman et al. 2022)—upholds racial inequities in political, legal, economic, health care, education, and criminal justice systems (Braveman et al. 2022; Feagan and Ducey 2018). As a result, structural and social conditions—including residential segregation, the inequitable allocation of social and health resources, concentrated poverty, over-representation in low-wage jobs and in the prison systems, and higher levels of chronic stress—cluster together to create higher barriers to health and wellness for Black, Latinx, Indigenous, and other communities of color (Egede and Walker 2020; Pirtle 2020). Moreover, historical exploitation and abuse by medical and research entities including the federal government (for example, the Tuskegee Syphilis Study) and present-day lived experiences of racial discrimination in health care settings have led to distrust in the medical establishment, eroding confidence in COVID-19 testing and vaccination (AuYoung et al. 2022; Neely et al. 2021; Willis et al. 2023).

The U.S. Department of Health and Human Services (HHS) responded by making significant investments in COVID-19 programs that prioritize health equity, such as the Administration for Strategic Preparedness and Response’s investments in home testing, the National Institutes of Health’s Rapid Acceleration of Diagnostics-– Underserved Populations (RADx-UP) initiative, and the Centers for Disease Control and Prevention’s Partnering for Vaccine Equity program. These programs have already generated evidence to develop new approaches to improve vaccine access and confidence for specific communities.

Federal agencies provided resources to increase COVID-19 testing and vaccination

- Federal agencies—including the U.S. Department of Health and Human Services, Department of Agriculture, Department of Homeland Security, and Housing and Urban Development—funded testing and vaccination programs in amounts ranging from $15 million to $5 billion.
- Recipients included state, tribal, and local governments, health centers, and community organizations.
- Some federal funding focused on increasing equitable access to tests and vaccines. Federal agencies also supplied COVID-19 tests and vaccines and established testing sites (CDC 2023g; HRSA 2022c; ASPR 2022).

Recognizing the need for additional evidence to support federal, state, and local efforts to close testing and vaccination gaps—and to identify useful lessons for future pandemics—the Office of the Assistant Secretary for Planning and Evaluation (ASPE) and the Office of the Assistant Secretary for Health (OASH) sponsored a mixed-methods study of best practices in COVID-19 testing and vaccination and routine vaccination for people who are medically or socially at disproportionate risk for COVID-19 or related adverse outcomes (Best Practices for COVID-19 Testing and Vaccination study). The goals of the study are to identify and examine promising and best practices to (1) increase COVID-19 testing awareness, access, and uptake; (2) increase confidence in, access to, and uptake of COVID-19 vaccines; and (3) improve confidence in, access to, and uptake of routinely recommended vaccines for children and adults during the COVID-19 pandemic. Mathematica is ASPE’s research partner for the Best Practices for COVID-19 Testing and Vaccination study and developed this report based on a targeted environmental scan of testing and vaccination programs serving populations facing disproportionate risks. Although the COVID-19 Public Health Emergency ended on May 11, 2023, the COVID-19 virus continues to cause illness, hospitalization, death, and disability (Schnirring 2023). Moreover, experts agree that another pandemic is possible, and even likely (Linder et al. 2023). Thus, findings from this study can support ongoing efforts to combat COVID-19 as well as efforts to prepare for future pandemics.

## B Purpose of the environmental scan

The environmental scan is an important first step to understand the range of programs intended to improve COVID-19 testing, COVID-19 vaccination, and routine vaccinations for the populations of focus for the study. Findings in this report will inform the design of other components of the study, including a national survey of local organizations that have implemented testing and vaccination programs and site visits to selected organizations. The study team used research questions in the following three topic areas to guide the environmental scan.

Contextual factors for programs. The environmental scan included a review of federal regulations and guidelines that provide context for programs designed to increase COVID-19 testing and vaccination among people who are medically or socially at disproportionate risk for COVID-19 or related adverse outcomes. We also looked for information about how programs have used resources (such as funding, staffing, and supplies) provided by local, state, or federal jurisdictions to increase COVID-19 testing and vaccination.

COVID-19 testing and vaccination program implementation and evaluation. A primary purpose of the environmental scan was to review information about how programs increased COVID-19 testing and vaccination in intended populations. Although the study initially developed research questions about slightly different outcomes or goals for COVID-19 testing and vaccination and routine vaccination—specifically, naming increased awareness as one goal of testing programs versus increased confidence for vaccination programs—the scan found that programs sought to increase both awareness and confidence for both testing and vaccinations, as well as to increase access. We also reviewed how programs identified their intended populations, how they evaluated their programs (for example, by measuring changes in uptake or use of testing and vaccines), and what data sources they considered for these tasks.

Routine vaccination. The environmental scan included a review of strategies that programs have used to ensure that children and adults were up to date on routine vaccinations during the pandemic, and how or if they addressed inequities in routine vaccination access and uptake.

## C Summary of methods

To inform this report, we conducted a targeted literature review of materials published from 2020 through January 2023,^4^ printed in English, and focused on the United States, and we interviewed key informants. See Appendix A for more detail on sources and methods.

Literature on testing and vaccination guidelines. We identified background information on COVID-19 testing, vaccination, and disparities and on routine vaccination through focused Google searches. We also searched relevant federal agency websites, such as Centers for Disease Control and Prevention (CDC), Food and Drug Administration (FDA), and Association of Public Health Laboratories (APHL).

Literature on policies and programs. We reviewed peer-reviewed and gray literature on programs focusing on COVID-19 testing and COVID-19 vaccination and routine vaccination during the pandemic. We created specialized search strings that included key words such as “program,” “initiative,” “campaign,” “model,” “intervention,” “policy,” or “strategy,” combined with terms related to the population of focus (people who are medically or socially at disproportionate risk of COVID-19 or related adverse outcomes). We searched the PubMed, CINAHL, SOCIndex, and Health Policy Reference Center bibliographic databases and Google using search strings for each program focus (COVID-19 testing, COVID-19 vaccination, and routine vaccination). For our Google search, we reviewed search results for each of these three program foci until we approached saturation indicated by duplicate links. This yielded roughly 40 results for each program focus. We also reviewed an inventory of federal programs related to COVID-19 testing, COVID-19 vaccinations, and routine vaccinations that ASPE provided.

Key informant interviews. We conducted 22 one-hour interviews with respondents implementing or funding COVID-19 testing and vaccination and/or routine vaccination programs. Respondents were representatives of health care organizations, local and state health departments, community-based organizations, academic institutions, foundations, and federal agencies. We identified key informants through recommendations from the project’s expert panel members and internet searches. We sought variation in organization type, geographic location, and population(s) of focus. We conducted all interviews virtually in February and March 2023, using interview guides tailored for key informants’ organization type. See Appendix B for more information on key informants and interview topics.

Analysis. We extracted information on specific programs from articles, websites, and our interview notes in an Excel-based tool. We used thematic inductive coding to identify themes within a taxonomy of program elements, including in program approaches, delivery strategies, implementation barriers, and implementation strategies (see Exhibit I.1).

Limitations. The environmental scan was purposive and targeted, rather than systematic. The findings in this report are not based on an exhaustive search of all relevant programs. They also privilege those programs that were able to publish findings—such as programs administered by universities and funded by federal grants—as well as those able to publish by January 2023. Some reports may be in progress and have not yet been published. Thus, findings do not represent all relevant programs or promising practices, and it is possible that our taxonomy of program elements organized by the goals of increasing awareness, confidence, access, and uptake would change with more (and more updated) data. In addition, sources may exclude programs for, or findings about, some groups of people at disproportionate risk of COVID-19 or related adverse outcomes, for example because they are small and excluded from the data sources that would help programs identify and serve them. We purposely limited the search of routine vaccination programs to those focused on halting the declining rates during the COVID-19 pandemic, but this limited our findings on general promising practices for encouraging routine vaccinations. We also acknowledge the inherent selection bias in limiting the search to materials printed in English. Finally, although understanding barriers to program implementation was a goal of the environmental scan, relatively few sources discussed this topic.

## D Key concepts and definitions

We define and provide examples of concepts central to the environmental scan in this section and in Exhibit I.1. We also explain how we use certain terms to describe findings. See Appendix C for a glossary with additional terms.

Use of the term “program.” For parsimony, we use program throughout the report to refer to any organized, planned, and ongoing change effort. Sources sometimes used different terms interchangeably, such as intervention and program, or described efforts labeled as programs, projects, or models in similar ways. We searched for a broad list of terms to ensure that we reviewed relevant practices, regardless of word choices in the sources we reviewed. We use specific terms such as “campaign” to describe our findings where such a term adds meaning or clarity. Policies can include guidelines, rules, regulations, laws, procedures, principles, or directions. Like programs, policies can also constitute interventions to reduce COVID-19 testing and vaccination and routine vaccination disparities. In this report, we focus on federal policies—primarily testing and vaccination guidelines, but also key federal legislation—that provide context for program-related findings. State-level policies varied widely. Although the sources we reviewed did not include in-depth descriptions of individual state policies, possibly because states are less likely to publish descriptions of their efforts, the Kaiser Family Foundation (2021) and Williams and others (2023) provide helpful syntheses.

Information on levels and actors. The sources we reviewed included programs at the local (neighborhood, city, county), state (or region of a state), multi-state, and national levels. Programs in our review often involved partnerships among funders, administrators, and implementers operating at different levels. For example, a program might have been funded at the federal level, administered by a state or county health department, and implemented by community-based organizations. The primary administrator or implementer was not always clear in the sources we reviewed. Many of the entities administering programs in this environmental scan were universities, possibly because of universities’ relatively greater ability to publish findings about programs they were involved in. Where possible, we include information on the level or location and entities administering the programs in our discussion of findings.

Terms for program elements and outcomes. Although other resources on COVID-19 testing and vaccination use different terms for program elements or group them differently, for example by describing all COVID-19 vaccination program elements as “strategies” (CDC 2022l), organizing findings according to the taxonomy in Exhibit I.1 allows for more precision in understanding program activities and promising practices for addressing testing and vaccine inequities. We used these concepts to organize findings about program delivery, implementation, and evaluation. Specifically, we categorized programs’ primary approaches and the strategies they use to enhance the effectiveness of their primary approaches. We organized findings on approaches and strategies according to whether they sought to increase testing and vaccination awareness, confidence, access, or uptake. For the most part, those efforts helped people overcome barriers to awareness, confidence, and access). Most programs in our review directly sought to increase awareness, confidence, or access; increased uptake is the desired result. However, a few programs used strategies that directly affected uptake, such as financial incentives.

Exhibit I.1 Key concepts, definitions, and examples

Concept | Definition | Examples
Policy | - A law, regulation, procedure, administrative action, incentive, or voluntary practice of governments and other institutions intended to influence systems development, organizational change, and individual behavior to promote improvements in health | - American Rescue Plan Act of 2021; - Public Readiness and Emergency Preparedness (PREP) Act (https://aspr.hhs.gov/legal/PREPact/Pages/default.aspx); - Funding policy and guidance, for example in notices of funding opportunities from the Health Resources and Services Administration (HRSA) and the Centers for Disease Control and Prevention (CDC)
Guideline | - A specific type of policy; a set of recommendations related to a particular topic provided by an agency and directed to states, public health practitioners, or individuals | - Centers for Disease Control and Prevention (CDC)’s evidence-based guidelines (https://www.cdc.gov/mmwr/volumes/71/su/su7101a1.htm?s_cid=su7101a1_w), such as:; - CDC guidelines for COVID-19 testing (https://www.cdc.gov/coronavirus/2019-ncov/symptoms-testing/testing.html); - CDC vaccination schedules for health care providers (https://www.cdc.gov/vaccines/schedules/hcp/index.html)
Program | - An organized, planned, and ongoing change effort, at the local, state, multi-state, or national level. A program may include multiple approaches. We use the term “program” to encompass a broad set of terms used by sources, such as intervention, project, model, or campaign. | - Say Yes! Covid Test (https://covid19.nih.gov/news-and-stories/communities-say-yes-covid-test) (National Institutes of Health); - One Vax Two Lives (https://reader.elsevier.com/reader/sd/pii/S0002937822004768?token=CBCDAE312CD8D0188F22DA6F13AFE1F7CC5C78E97433808334281554B364B3FA2928F9AC362EEA39FAAD625D3A705AC3&originRegion=us-east-1&originCreation=20230328231440) (University of Washington); - Catch Up to Get Ahead (https://www.hhs.gov/immunization/catch-up/index.html) (U.S. Department of Health and Human Services)
Program focus | - The type of program or primary topic of a program, based on the three overarching study objectives | - COVID-19 testing; - COVID-19 vaccination; - Routine vaccination
Program approach | - The primary mechanism(s) or vehicle(s) programs used to achieve intended COVID-19 testing, COVID-19 vaccination, and routine vaccination outcomes | - Mass testing/vaccination clinics; - Testing/vaccination in health care settings; - Community testing/vaccination clinics; - Mobile testing/vaccination clinics; - In-home testing/vaccination; - Vaccine education events or outreach
Strategies to facilitate delivery of program approaches | - Strategies or activities designed to make the program approach effective, focusing on the needs of program participants. Specific delivery strategies can be used across multiple approaches to further enhance their effectiveness. | - Partner with trusted community organizations and leaders to deliver messaging and interventions; - Develop clear, accessible, and culturally tailored messaging, delivered through multiple channels; - Provide walk-up options and expanded hours to increase access; - Remove need for physician referral, health insurance, or other documentation
Strategies to facilitate implementation of program approaches | - Activities designed to facilitate implementation of program approaches, focusing on program personnel and administration | - Ensure staff have adequate training and supplies; - Hold planning meetings between partnering organizations
Program outputs | - Proximate measures of the program’s performance, including the quantity and quality of service delivery | - Number of testing or vaccination events; - Program reach, such as the number of people reached through outreach and education; - Number of COVID-19 tests administered; - Number of COVID-19 vaccines delivered; - Number of influenza vaccines delivered
Program outcomes | - Measures of changes among program recipients and program effects on intended populations | - Changes in testing and vaccine confidence and awareness; - Changes in rates of testing and vaccination; - Changes in COVID-19 incidence and deaths

## E Organization of the report

The report is organized as follows. Section II reviews populations at disproportionate risk for COVID-19 or adverse outcomes, common barriers to testing and vaccination services experienced by these populations, and populations prioritized by the programs we reviewed. The next three sections review findings on COVID-19 testing (Section III), COVID-19 vaccination (Section IV), and routine vaccination (Section V). Each section begins with information on relevant federal guidelines and changes in those guidelines over time. We then describe programs’ primary approaches, delivery strategies, implementation challenges, and implementation strategies.^5^ In Section VI, we provide an overview of data sources that are used, or can be used, to identify communities in need of COVID-19 testing, COVID-19 vaccination, and routine vaccination services and to measure the outcomes of programs’ efforts. We conclude by summarizing broad themes and implications for future work to address social inequities in COVID-19 testing and vaccination, in routine vaccinations, and in responses to the next pandemic.

4 However, information on COVID-19 vaccination guidelines in Section IV and on routine vaccination guidelines in Section V is current as of April 2023.

5 At the time of this reporting, programs were at various stages of implementation. Some programs were completed, others ongoing, and others had not yet begun. For readability, we use the past tense throughout, except in Section II, where we describe (1) populations that are medically or socially at disproportionate risk of COVID-19 or related adverse outcomes or (2) barriers to COVID-19 testing and vaccination and routine vaccination services. Many risks and barriers are ongoing.