# Appendix C Glossary of terms

Exhibit C.1 Glossary of terms

Term | Definition
Equity concepts
Health inequity | Health disparities that are deemed unfair or that stem from some form of injustice (Meghani & Gallagher 2008)
Health-related social needs | Barriers to health, experienced at the individual level, that are within the purview of health care providers to identify and help address, such as housing instability, safety needs, food insecurity, and financial strain, among others (CMS 2022 (https://innovation.cms.gov/media/document/ahcm-screeningtool-companion))
Social determinants of health | The conditions in which people are born, grow, work, live, worship, and age, including neighborhood environments, schools, and the workplace (World Health Organization 2023)
Structural racism | Public and private policies, norms, and cultural representations that inherently lead to unequal freedom, opportunity, value, resources, advantage, restrictions, constraints or disadvantage for individuals and populations according to their race or ethnicity (Braveman et al. 2022)
Program goals
Awareness | The degree to which individuals have knowledge of the need for, and availability of, recommended vaccines [or testing] and their objective benefits and risks (Thomson et al. 2016)
Access | The ability of individuals to be reached by, or to reach, recommended vaccines [or testing] (Thomson et al. 2016)
Confidence | Trust in (1) the effectiveness and safety of vaccines [or testing]; (2) the system that delivers them, including the reliability and competence of the health services and health professionals and (3) the motivations of policymakers who decide on the needed vaccines [or testing] (MacDonald 2015)
Uptake | The action of getting a vaccine or test ^a^
Metrics
Testing or vaccination rate | Uptake of COVID-19 testing or vaccination, generally measured as a proportion of the eligible population, or: # people tested or vaccinated/total eligible population x 100% (Leuchter et al. 2022)
Test positivity rate | Sometimes called the “positivity rate,” quantifies the percentage of all coronavirus tests performed that are actually positive, or: (positive tests)/(total tests) x 100% (Johns Hopkins 2020)
Terms relevant to study goals
Promising practices | A practice that worked within one organization, shows promise for becoming a best practice, has some objective basis for a claim of effectiveness, and has potential for replication among other organizations (Brennan et al. 2011 (https://pubmed.ncbi.nlm.nih.gov/21219169/)).
Best practices | A practice that has been proven to be effective in improving population health through rigorous evaluations. It is effective in a specific real-life setting and likely to be replicable in other settings (Brennan et al. 2011 (https://pubmed.ncbi.nlm.nih.gov/21219169/)).

a The term “uptake” was used in many ways across the sources in our scan, as well as the epidemiology literature more broadly. Some sources use uptake synonymously with rate, which is a population-level measure (for example, Leuchter et al. 2022). For the purposes of this report, we define uptake as an individual-level action or outcome.