# Appendix B Organizations included in key informant interviews

Exhibit B.1 presents the types of organizations that key informants represent and number of interviews with each type of organization.

Exhibit B.1 Organizations included in key informant interviews

Category | Number of organizations | Description
Clinical/local providers | 4 clinical organizations/health systems | - FQHC in the Midwest; - Tribal health system in the West; - National pharmacy retailer; - National pharmacy association
Clinical/local providers | 2 local health departments | - Local health department in the South; - Local health department in the Midwest
Clinical/local providers | 1 academic institution | - Academic institution in the West
State health departments | 2 state health departments | - State health department in the Northeast; - State health department in the South
CBOs | 6 CBOs | - CBO in Midwest that serves a large immigrant population; - CBO in West that that works to advance health and racial equity among the populations they serve; - CBO in South that works in 3 primarily rural counties; - CBO that uses media and communications strategies to serve Black populations, primarily in the South.; - CBO focused in tribal populations on Northwest; - CBO in South that primarily serves Latinx populations
Funders | 2 non-federal funders | - Foundations that fund health interventions in the U.S. and abroad.
Funders | 5 federal funders | - Federal agencies that fund health services/ public health programs and respond to disasters

We developed and used semi-structured interview guides tailored for the following categories of key informants: (1) clinical and local providers, (2) state health departments, (3) CBOs, and (4) funders. Exhibit B2. presents the research questions covered in these interview guides, by respondent type. We developed interview questions for each category of key informants related to the research questions.

Exhibit B.2 Research questions covered interview guides, by respondent type

| Clinical/local providers | State health depts | CBOs | Funders
RQ1. [Policy context] What policies did local, state, or federal jurisdictions use to increase COVID-19 testing and vaccination (for example, public health system structure, laws, and regulations, etc.) in underserved populations? What policies were effective at increasing outcomes of interest? | | X | | X
RQ2. [Resource distribution/Administrative preparedness] How did programs use resources (such as funding, staffing, materials) provided by local, state, or federal jurisdictions to increase COVID-19 testing and vaccination? What challenges did programs face using resources? What resources were effective? | X | X | X | X
RQ3. [Program definition] What key programs deliver COVID-19 testing and vaccination services to underserved populations? | X | X | X | X
RQ3. [Program implementation] (1) Through what entities/mechanisms are programs delivered? (2) What are the combinations of intervention strategies that make up the programs? (3) Do the programs/intervention strategies vary by population? (4) What are the barriers and facilitators to implementing these programs/intervention strategies? (5) How has program delivery changed over time? | X | | X | X
RQ4. [Ensure equity] How do programs identify the populations they intend to receive the COVID-19 testing and vaccination services? How are data, metrics (indices, data tools), or intentional strategies used to identify the intended populations, including strategies to identify underserved populations that existed prior to the pandemic? How has this changed over time? | X | X | X | X
RQ 8. [Evaluating programs] How are COVID-19 testing and vaccination programs in underserved population(s) being evaluated? Are there metrics (for example, indices, data tools) used to identify and assess implementation and program outcomes? What data or resources are needed to develop these metrics? | X | X | | X
RQ10. [Ensuring routine vaccinations] How have federal, state, or local jurisdictions ensured that children and adults are up-to-date for routinely recommended vaccines during the pandemic? | X | X | | X
RQ12. [Novel strategies for bundling vaccines] What novel strategies to promote COVID-19 vaccines simultaneously with routine vaccines are being used? What strategies or resources from the COVID-19 vaccination rollout can be utilized for routinely recommended vaccines for children and adults? | X | X | | X