# Appendix A Additional information on research methodology for the literature review

Exhibit A.1 lists the search terms and search strings we used to identify scholarly and gray literature.

Exhibit A.1 Literature search terms and search strings

Category | Search term
Search terms for scholarly literature
Subjects | 1. COVID^*^ AND test^*^; 2. COVID^*^ AND vaccin^*^ OR immuniz^*^ OR immunis^*^ OR innoculat^*^; 3. Routine OR compulsory^*^ OR scheduled OR mandatory OR Monovalent OR Bivalent OR booster) AND (vaccin^*^ OR immunis^*^ OR immuniz^*^ OR innoculat^*^)
Population of interest | (race OR racial OR racism OR ethnic^*^ OR nonwhite OR Black^*^ OR (African N2 American) OR Hispanic OR Latin^*^ OR Mexican^*^ OR Dominican^*^ OR Haitian^*^ OR Asian^*^ OR Hmong OR Vietnamese OR (Native N2 American) OR (American N2 Indian) OR (pacific N2 islander) OR (Native N2 Hawaiian) OR indigenous OR native^*^ OR Indian^*^ OR tribe OR tribal OR refugee^*^ OR immigrant^*^ OR undocument^*^ OR elder^*^ OR (older N2 adult) OR (limited N2 English) OR disabilit^*^ OR disabled OR Medicaid OR rural OR impair^*^ OR homeless^*^ OR incarcerated OR (chronic^*^ N2 (ill OR illness)) OR “chronically ill” OR pregnan^*^ OR “low income” OR poor OR poverty OR lesbian OR gay OR “bi-sexual” OR bisexual OR transgender OR LGBTQ^*^ OR “at risk” OR “high risk” OR minorit^*^ OR marginali^*^ OR discrimin^*^ OR segregat^*^ OR “under-insured” OR underinsured OR uninsured OR “under-resourced” OR underresourced OR vulnerabl^*^ OR disadvantag^*^)
Topic | ( (uptake OR confiden^*^ OR hesitan^*^ OR trust OR mistrust OR barrier OR program^*^ OR interven^*^ OR initiat^*^ OR incentiv^*^ OR implement^*^ OR policy OR policies OR coverage OR strateg^*^ OR educat^*^ OR expand^*^ OR communit^*^ OR clinic^*^ OR progress^*^ OR challeng^*^ OR attitude^*^ OR measur^*^ OR practice^*^ OR campaign^*^ OR study OR model^*^ OR respon^*^ OR resource^*^ OR recommend^*^ OR opportunit^*^ facilitat^*^ OR aware^*^ OR Local^*^ OR “Community-Based” OR communit^*^ OR “Place-Based” OR “Local Health” OR Jurisdiction^*^ OR “Indian Health” OR IHS OR “Federally Qualified” OR “Health Center^*^” OR FQHC OR Pharmac^*^ OR nonprofit OR “Non-profit” OR City OR cities OR County OR counties OR State OR states OR Territor^*^ OR Federal^*^ OR Nationwide OR Tribal) ) OR AB ( (uptake OR confiden^*^ OR hesitan^*^ OR trust OR mistrust OR barrier OR program^*^ OR interven^*^ OR initiat^*^ OR incentiv^*^ OR implement^*^ OR policy OR policies OR coverage OR strateg^*^ OR educat^*^ OR expand^*^ OR communit^*^ OR clinic^*^ OR progress^*^ OR challeng^*^ OR attitude^*^ OR measur^*^ OR practice^*^ OR campaign^*^ OR study OR model^*^ OR respon^*^ OR resource^*^ OR recommend^*^ OR opportunit^*^ facilitat^*^ OR aware^*^ OR Local^*^ OR “Community-Based” OR communit^*^ OR “Place-Based” OR “Local Health” OR Jurisdiction^*^ OR “Indian Health” OR IHS OR “Federally Qualified” OR “Health Center^*^” OR FQHC OR Pharmac^*^ OR nonprofit OR “Non-profit” OR City OR cities OR County OR counties OR State OR states OR Territor^*^ OR Federal^*^ OR Nationwide OR Tribal) )
Geography | “United States” OR america^*^ OR “USA” OR alabama OR alaska OR arizona OR arkansas OR california OR colorado OR connecticut OR delaware OR “District of Columbia” OR florida OR georgia OR hawaii OR idaho OR illinois OR indiana OR iowa OR kansas OR kentucky OR louisiana OR maine OR maryland OR massachusetts OR michigan OR minnesota OR mississippi OR missouri OR montana OR nebraska OR nevada OR “New Hampshire” OR “New Jersey” OR “New Mexico” OR “New York” OR carolina OR dakota OR ohio OR oklahoma OR oregon OR pennsylvania OR “Rhode Island” OR tennessee OR texas OR utah OR vermont OR virginia OR washington OR wisconsin OR Wyoming
COVID-19 testing | (Covid testing) AND (race\|minority\|vulnerable\|underserved) AND (program\|model\|initiative\|campaign\|strategy)
COVID-19 vaccination | (Covid vaccination) AND (race\|minority\|vulnerable\|underserved) AND (program\|model\|initiative\|campaign\|strategy)
Routine vaccination | (routine vaccination) AND Covid AND (race\|minority\|vulnerable\|underserved) AND (program\|model\|initiative\|campaign\|strategy)

* Asterisks denote search terms that are root words and that we searched in the sources with a variety of word endings. For example, the search engine searched the term “test^*^” as “test”, “tests”, “testing”, and “tester”.

Exhibit A.1. provides information on how many sources we identified through our searches and through items provided by ASPE, how many sources screened in, how many sources Mathematica content experts identified as highly relevant, how many sources we reviewed, and source categories. We first screened in sources based on a review of the source title if they met the following inclusion criteria: (1) source title discusses COVID-19 testing or COVID-19 vaccination best practices, recommendations, or guidance; (2) source title discusses routine vaccination best practices, recommendations, or guidance; or (3), source title discusses COVID-19 vaccination, COVID-19 testing, or routine vaccination programs or initiatives. We also applied the following exclusion criteria: (1) source was published before 2020; (2) source does not focus on the United States. We further prioritized sources by reviewing the title and abstract for explicit discussion of programs, initiatives, campaigns, models, and strategies.

Exhibit A.2 Sources identified, screened, deemed highly relevant, and reviewed

Note: The reference list includes more than the 127 reviewed papers because we conducted supplementary searching to inform complete descriptions of barriers to COVID-19 testing and vaccination, structural racism, federal guidelines and recommendations on testing and vaccination, and other topics.

^a^ We reviewed all sources deemed highly relevant.

^b^ Sources with the "Other" designation include items provided by ASPE, such as gray literature and links to federal programs that we included after de-duplicating sources.

A blue flowchart displays the number of sources identified and retained at each stage of the enviromental scan. The header of the first satge reads as follows. 1,079 sources were identified. 931 were peer-reviewed articles, 120 were found through Google, and 28 sources were identified in other ways, including items provided by ASPE. The second stage was screning. 460 articles were screened in to the review, including 395 peer-reviewed articles, 44 sources found though Google, and 21 sources found in other ways. The last stage is full review of relevant sources, 127 in total. This includes 62 peer-reviewed articles, and all 44 sources found through Googleand the 21 sources identified in other ways.

Exhibit A.3 Sources reviewed and included in analysis

Source type or focus | Count
COVID-19 testing | 35
COVID-19 vaccinations | 33
Routine vaccinations | 6
Federal programs | 30
Synthesis papers^a^ | 23

a Sources included in the “Synthesis papers” group are sources that we identified through our peer-reviewed literature and gray literature searches that synthesized information on multiple programs, initiatives, campaigns, models or strategies at a high level or described general best practices related to COVID-19 vaccinations, COVID-19 testing, or routine vaccinations, but did not describe one program in depth. They also included papers on barriers to testing and vaccination.