# 8 REFERENCES

Abrantes-Metz, R. M., Adams, C. P. & Metz, A., 2004. Pharmaceutical Development Phases: A Duration Analysis - Working Paper 274, Washington, DC: Federal Trade Commission, Bureau of Economics.
Adams, C. & Brantner, V., 2006. Estimating the cost of new drug development: is it really 802 million dollars?. Health Affairs (Millwood), 25(2), pp. 420–428.
Adams, C. & Brantner, V., 2010. Spending on new drug development. Health Economics, 19(2), pp. 130–141.19247981
BiomedTracker, 2016. Clinical Development Success Rates 2006-2015, Washington, DC: Biotechnology Innovation Organization.
Chit, A. . 2015. The Opportunity Cost of Capital: Development of New Pharmaceuticals. Inquiry: A Journal of Medical Care Organization, Provision, and Financing, Volume 52, p. 0046958015584641. doi: 10.1177/0046958015584641.25933615
Chit, A. . 2014. Toward More Specific and Transparent Research and Development Costs: The Case of Seasonal Influenza Vaccines. Vaccine, Volume 32, p. 3336–3340.23830976
Cutting Edge Information, LLC, 2013. Clinical Development and Trial Operations – Protocol Design and Cost per Patient Benchmarks, Research Triangle Park, NC: Cutting Edge Information, LLC.
Damodaran Online, 2018. Data: Archives. [Online] Available at: http://people.stern.nyu.edu/adamodar/New_Home_Page/dataarchived.html [Accessed 12 November 2019].
Damodaran Online, 2019. Cost of Capital by Sector (US). [Online] Available at: http://people.stern.nyu.edu/adamodar/New_Home_Page/datafile/wacc.htm [Accessed 12 November 2019].
DiMasi, J. A., Grabowski, H. G. & Hansen, R. W., 2016. Innovation in the pharmaceutical industry: new estimates of R&D costs. Journal of health economics, Volume 47, pp. 20–33.26928437
DiMasi, J., Feldman, L., Seckler, A. & Wilson, A., 2010. Trends in Risks Associated With New Drug Development: Success Rates for Investigational Drugs. Clnical Pharmacology & Therapeutics, 87(3), pp. 272–277.
DiMasi, J. & Grabowski, H., 2007. The cost of biopharmaceutical R&D: is biotech different?. Managerial and Decision Economics, 28(4–5), pp. 469–479.
DiMasi, J., Grabowski, H. & Vernon, J., 2004. R&D costs and returns by therapeutic category. Drug Information Journal, 38(3), pp. 211–223.
DiMasi, J., Hansen, R. G. H. & Lasagna, L., 1991. Cost of innovation in the pharmaceutical industry. Journal of Health Economics, Volume 10, pp. 107–142.10113009
DiMasi, J., Hansen, R. & Grabowski, H., 2003. The Price of Innovation: New Estimates of Drug Development Costs. Journal of Health Economics, 22(2), pp. 151–185.12606142
Eastern Research Group, Inc., 2022. Evaluating the Potential Impacts of Different Clinical Trial Strategies on Drug, Preventive Vaccine, and Therapeutic Complex Medical Device Development, Washington, DC: US Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation.
Federal Register, 2018. Prescription Drug User Fee Rates for Fiscal Year 2019. [Online] Available at: https://www.federalregister.gov/documents/2018/08/01/2018-16387/prescription-drug-user-fee-rates-for-fiscal-year-2019 [Accessed 25 August 2024].
Gouglas, D. . 2018. Estimating the cost of vaccine development against epidemic infectious diseases: A cost minimization study. The Lancet, Volume 6, pp. e1386–e1396.30342925
Harrington, S., 2012. Cost of Capital for Pharmaceutical, Biotechnology, and Medical Device Firms. In: P. Danzon & S. Nicholson, eds. The Oxford Handbook of the Economics of the Biopharmaceutical Industry. New York: Oxford University Press, pp. 75–99.
Hsiue, E., Moore, T. & Alexander, G., 2020. Estimated Costs of Pivotal Trials for U.S. Food and Drug Administration-approved Cancer Drugs, 2015-2017. Clinical Trials, 17(2), pp. 119–125. doi: 10.1177/1740774520907609.32114790
Jayasundara, K. . 2019. Estimating the clinical cost of drug development for orphan versus non-orphan drugs. Orphanet Journal of Rare Diseases, 14(1), p. 12.30630499
Lansdowne, L. E., 2020. Exploring the Drug Development Process. [Online] Available at: https://www.technologynetworks.com/drug-discovery/articles/exploring-the-drug-development-process-331894 [Accessed 20 July 2020].
Light, D. & Warburton, R., 2011. Demythologizing the High Costs of Pharmaceutical Research. BioSocieties, Volume 6, pp. 34–50. doi: 10.1057/biosoc.2010.40.
Makower, J., Meer, A. & Denend, L., 2010. FDA Impact on U.S. Medical Device Innovation: A Survey of over 200 Medical Technology Companies, San Francisco, CA: Medical Device Manufacturers Association (MDMA) and National Venture Capital Association (NVCA).
Martin, L., Hutchens, M. & Hawkins, C., 2017. 2017. Nature Reviews: Drug Discovery, 16(March), p. 157.
Medidata Solutions, 2012. Custom tabulation on clnical trial costs by phase and therapeutic area. s.l.:s.n.
Mestre-Ferrandiz, J., Sussex, J. & Towse, A., 2012. The R&D Cost of a New Medicine, London, UK: Office of Health Economics.
Moore, T. J., Heyward, J., Anderson, G. & Alexander, G. C., 2020. Variation in the estimated costs of pivotal clinical benefit trials supporting the US approval of new therapeutic agents, 2015–2017: a cross-sectional study. BMJ Open, Volume 10, p. e038863.
PAREXEL International Corp., 2017. PAREXEL Biopharmaceutical R&D Statistical Sourcebook 2017/2018. Newton, MA: PAREXEL International Corp..
Paul, S. . 2010. How to Improve R&D Productivity: The Pharmaceutical Industry’s Grand Challenge. Nature Reviews: Drug Discovery, 9(3), pp. 203–214.20168317
Prasad, V. & Mailankody, S., 2017. Research and development spending to bring a single cancer drug to market and revenues after approval. JAMA Internal Medicine, 177(11), pp. 1569–1575.28892524
Sertkaya, A., Wong, H.-H., Jessup, A. & Beleche, T., 2016. Key cost drivers of pharmaceutical clinical trials in the United States. Clinical Trials, 13(2), pp. 117–126.26908540
Stergiopoulos, S., Kim, J. & Getz, K., 2013. Characterizing the Cost of Non-Clinical Development Activity - Understanding a Critical R&D Segment. Contract Pharma, 5 June.
U.S. Food and Drug Administration, 2016a. Non-Inferiority Clinical Trials to Establish Effectiveness - Guidance for Industry, Silver Spring, MD: U.S. Food and Drug Administration, Center for Drug Evaluation and Research.
U.S. Food and Drug Administration, 2018b. The Drug Development Process. [Online] Available at: https://www.fda.gov/patients/learn-about-drug-and-device-approvals/drug-development-process [Accessed 17 July 2020].
U.S. Food and Drug Administration, 2018j. Transfer of Therapeutic Products to the Center for Drug Evaluation and Research (CDER). [Online] Available at: https://www.fda.gov/about-fda/center-biologics-evaluation-and-research-cber/transfer-therapeutic-products-center-drug-evaluation-and-research-cder [Accessed 15 August 2020].
U.S. Food and Drug Administration, 2018l. Custom query from FDA’s DASH database, Silver Spring, MD: s.n.
U.S. Food and Drug Administration, 2019d. Custom data pull from FDA CDER’s internal tracking database. Silver Spring, MD: U.S. Food and Drug Administration.
U.S. Food and Drug Administration, 2020b. Learn About FDA Advisory Committees. [Online] Available at: https://www.fda.gov/patients/about-office-patient-affairs/learn-about-fda-advisory-committees [Accessed 28 July 2021].
U.S. Food and Drug Administration, 2021a. Conduct of Clinical Trials of Medical Products During the COVID-19 Public Health Emergency - Guidance for Industry, Investigators, and Institutional Review Boards. [Online] Available at: https://www.fda.gov/media/136238/download [Accessed 7 July 2021].
Wong, C., Siah, K. & Lo, A., 2019. Estimation of Clinical Trial Success Rates and Related Parameters. Biostatistics, 20(2), pp. 273–286.29394327
Wouters, O. J., McKee, M. & Luyten, J., 2020. Estimated research and development investment needed to bring a new medicine to market, 2009-2018. JAMA, 323(9), pp. 844–853.32125404