# ACKNOWLEDGMENTS

We gratefully acknowledge Amber Jessup (HHS/OIG/OMP) and Trinidad Beleche (HHS/OS/ASPE) for their leadership, guidance, and input throughout this study. We also would like to thank all of our expert panel members for their input on the potential impacts of different strategies on medical product development costs. Many others involved in clinical research, including pharmaceutical/biopharmaceutical company representatives, CRO personnel, and industry experts, provided valuable information for the study. We are grateful to them all for sharing their opinions and experiences with us. We also would like to acknowledge all federal experts noted below for providing guidance throughout the study and/or reviewing study report and findings.

- Hui-Hsing Wong
  ASPR/BARDA
- Chazeman Jackson
  (Formerly at ASPE)
- Jessica White
  (HHS/ASPE)
- Julie Vaillancourt
  FDA/CBER/CBER/OD
- Owen Faris
  FDA/CDRH/CDRH/OPEQ
- Mike Lanthier
  FDA/OC/OPLIA/OEA
- Murray Sheldon
  FDA/CDRH/CDRH/OSPTI
- Peter Stein
  FDA/CDER/CDER/OND
- Ryan Conrad
  FDA/CDER/CDER/OSP/OPSA/ES
- Daniel Ramsey
  FDA/CDRH/CDRH/OPEQ/OCEA/DCEAI
- Kevin Wood
  FDA/OC/OPLIA/OEA/ES
- Thomas Henry
  FDA/OC/OPLIA/OEA/ES
- Ruben Jacobo-Rubio
  FDA/OC/OPLIA/OEA/ES
- Kirk Kerr
  Formerly at FDA/CDER
- Jonathan Jarow
  Formerly at FDA/CDRH
- Michael Kurilla
  NIH/NCATS/DCI
- Cynthia Boucher
  NIH/NCATS/DCI
- Petra Kaufmann
  (Formerly at NIH/NCATS)