# EXECUTIVE SUMMARY

The cost of bringing a medical product to the U.S. market has been increasing and clinical trials constitute a large portion of these costs. In drug development, the clinical phase lasts an average of around 95 months compared to 31 months for the non-clinical phase and accounts for 69 percent of overall R&D costs (DiMasi, et al., 2016). Clinical trials contribute significantly to the rising cost trend as they have become more expensive, complex, and lengthier over time. Thus, there is ongoing interest in reducing the overall cost of medical product development by improving the efficiency of clinical trials conducted in support of regulatory submission for marketing approval.

This study quantified the potential impacts of the following strategies on the cost, duration, and phase transition probability associated with drug development stages:

▪ Mobile technologies—Mobile technologies can include cell phones, wearable trackers, and other devices that capture data directly from patients. Electronic data capture means capturing study data in electronic format. The strategy could entail encouraging the use of mobile and other technologies in clinical trials and the development process as a whole and clarifying requirements around their use.
▪ Simplified clinical trial protocols and reduced amendments—The strategy could entail encouraging sponsors to simplify clinical trial protocols, where possible, ensuring that they have a clear understanding of what is required by FDA and what is superfluous.
▪ Reduced source data verification (SDV)—Source data verification is the process of comparing data collected throughout the clinical trial to the original source of information to verify data integrity. The strategy could entail engaging sponsors in discussions on the topic of data and site monitoring to ensure that they are aware of the FDA guidance stating that 100 percent source data verification is not required, as well as continuing to educate reviewers on this policy.
▪ Improvements in FDA review efficiency and interactions—The strategy could entail providing more opportunity to identify, discuss, and resolve substantive issues during the review, continuing to educate FDA reviewers on changes in FDA policy, and providing more transparency about what endpoints are required. However, the strategy does not account for the additional resource burden on FDA associated with implementing these strategies.
▪ Staged approval—Staged approval could entail granting provisional marketing approval to market a drug after safety and basic efficacy have been shown, and then continuing to collect additional safety and efficacy data. This would reduce the threshold for initial approval, perhaps with a limited patient population, and then gradually expand it as more data are collected.
▪ Biomarkers as surrogate endpoints—Biomarkers as surrogate endpoints are biological indicators that may correlate with the desired clinical endpoint, for example when it would take a long time for the clinical endpoint to become evident. The strategy could entail clarifying the path to biomarker validation or encouraging collaboration between academics, public entities, and industry to develop and validate biomarkers for use as surrogate endpoints.
▪ Electronic health records—EHRs, used here as being synonymous with electronic medical records (EMRs), are digital versions of the data collected when a patient visits a healthcare provider’s office. The strategy could entail encouraging sponsors to use EHRs for patient and physician recruitment or to collect clinical endpoints.
▪ Patient registries—A patient registry is an organized system that uses observational study methods to collect uniform data to evaluate specified outcomes of a disease or condition for a population. Registries include those established by a patient organization for a particular disease as well as registries that are sometimes established by the manufacturer and used as a post-marketing study. The strategy could entail encouraging sponsors to use registry data for patient and physician recruitment or to collect clinical endpoints for use in a clinical trial, where possible.
▪ Adaptive design—An adaptive design allows modifications to the trial and/or statistical procedures of the trial after its initiation without undermining its validity and integrity. The strategy could entail clarifying FDA’s policies on whether certain types of adaptive trial design are acceptable and encouraging their use.
▪ Standardized contracts—Standardized contracts are contract templates for use in sponsor-initiated multi-site trials, intended to reduce the complexity and duration of contract negotiations for clinical trial studies. The strategy could entail encouraging the use of master contracts and standardized contracts or compiling existing resources into a central location.

The strategies listed above were identified in ERG (2022) via a literature review conducted during the 2016-2018 period. Since that time, several of the strategies included herein were adopted and additional strategies have emerged, such as remote patient monitoring and virtual visits, which gained widespread adoption due to the COVID-19 pandemic. Additionally, recognizing the challenges of conducting clinical trials during a public health emergency, FDA issued new guidance containing nonbinding recommendations on a range of issues, including the use of virtual patient visits, remote monitoring of clinical sites, and use of real-world data in drug applications (U.S. Food and Drug Administration, 2021a). Given the timing of the literature review and analyses, this report does not address these new developments.

To facilitate the evaluation of the above-mentioned strategies, the study also included the development of a cost model for drugs. Our model used data from a variety of sources (public and non-public) and widely accepted accounting methods. We estimate the average out-of-pocket cost per drug at $172.7 million, which is significantly lower than published findings that used data reported by primarily large pharmaceutical companies. After accounting for cost of failures and capital, our estimate of $879.3 million is also generally lower than most published estimates. Our analysis also shows that clinical trials comprise the largest portion of overall drug development costs at $117.4 million which accounts for around 68 percent of out-of-pocket R&D expenditures.^1^

The strategy with the largest expected impact on overall development costs across all therapeutic areas is Improvements in FDA Review Process Efficiency and Interactions (−27.1 percent), followed by Adaptive Design (−22.8 percent), and implementation of a Simplified Clinical Trial Protocols and Reduced Amendments (−22.2 percent). Those strategies with the lowest expected development cost savings across all therapeutic areas include Use of Patient Registries (−9.9 percent), use of Biomarkers as Surrogate Endpoints (−13.3 percent), Electronic Health Records (−13.6 percent), and use of Standardized Contracts (−14.8 percent).

1 The model details and key findings regarding development costs are also available at Sertkaya, et al. (2016).