# 7 CONCLUSIONS

Similar to other published studies (DiMasi, et al., 2016; Wouters, et al., 2020; Prasad & Mailankody, 2017; Makower, et al., 2010; Chit, et al., 2014; Gouglas, et al., 2018), we find that clinical trials comprise the largest portion of overall drug development costs (Table 11). Clinical phase costs account for around 68 percent of out-of-pocket R&D expenditures for drugs. While our finding on the relative contribution of clinical trial costs to overall R&D expenditures is in line with other published studies, the estimated magnitude of these costs is different. We find that the clinical phase costs around $117.4 million out-of-pocket on average (ranging from $55.3 for genitourinary system to $255.1 million for pain and anesthesia drugs) in 2018 dollars compared to $386.8 million^9^ reported by DiMasi et al. (2016) and $319.3 million (ranging from $73.8 million to $2,119.9 million) reported by Wouters et al. (2020).

Despite the disproportionately high contribution of non-clinical phase costs to overall expected capitalized development costs, there is very little data on non-clinical phase costs. A 2012 study by Tufts CSDD estimated the non-clinical costs supporting a drug development program at $7.2 million, ranging from around $815,000 to $23.4 million with chemistry and manufacturing control activity costs representing the largest share at approximately 50 percent, followed by toxicology studies comprising nearly 25 percent, and pharmacology studies comprising 10 percent of the total non-clinical budget (Stergiopoulos, et al., 2013).^10^ This earlier estimate of non-clinical costs is substantially lower than the updated estimate in DiMasi et al., (2016), where the figure is extrapolated using the ratio of total pre-human development costs to total R&D spending, 42.9 percent; the approach generally adopted in this study.^11^ Given the sizable contribution of non-clinical phase costs to overall expected capitalized costs, further research into this stage is needed.

Using the information from experts and other relevant data on drug development costs, we estimate how implementation of the strategies impact drug development costs (Figure 2).

Improving FDA review process efficiency and interactions has the largest projected impact (−27.1 percent) on overall development costs across all therapeutic areas. This is followed by adaptive design (−22.8 percent), and implementation of simplified clinical trial protocols and reduced amendments (−22.2 percent). Strategies with the lowest, but still sizeable, expected development cost savings include the use of patient registries (−9.9 percent), biomarkers as surrogate endpoint (−13.3 percent), electronic health records (−13.6 percent), and use of standardized contracts (−14.8 percent).

Figure 2 Estimated Impacts on Expected Capitalized Development Costs (Inclusive of Post-approval Costs) for Drugs Across Strategies (in Percentages)

Notes: The zero percentages represent those cases where an expert indicated that the strategy was not relevant to a particular phase and/or cost, duration, or probability of phase transition success associated with that phase.

The graphic shows the ranking of the ten clinical trial strategies examined from largest to smallest impacts.

There are several limitations to this study. First, the impact estimates associated with the strategies identified represent the collective opinion of a small expert panel. As with any expert elicitation study, the opinions of experts are subject to known biases, such as availability, over/under-confidence, and representativeness. Second, the mental model each expert used in thinking about a strategy, i.e., what it encompasses and how it is implemented, is unknown but likely highly varied. The cognitive burden of the elicitation, which involved inquiring about hundreds of parameters (Eastern Research Group, Inc., 2022), required a trade-off between depth and breadth, precluding in-depth follow-up discussions with the expert participants. Third, as noted earlier, there have been significant developments in clinical research due to the COVID-19 pandemic that are not captured due to the timing of this study. Significant headway has been made in adopting several strategies highlighted in this study according to recent discussions with experts and federal staff.

9 The corresponding value reported in DiMasi et al. (2016) is $339.3 million in 2013 dollars.

10 The corresponding values reported in Stergiopoulos, et al. (2013) are $6.2 million, $698,000, and $20 million in 2012 dollars.

11 Since we had estimates of average non-clinical duration and transition success probability, we used the preclinical spending ($430 million) and clinical costs ($965 million) per approved drug reported in Figure 2 of DiMasi et al (2016) ,which translates to a ratio of 44.6 percent—1.7 percentage points higher than the 42.9 percent figure used in other studies.