# 6 DISCUSSION

It is difficult to directly compare cost of drug development estimates across different studies. As shown in multiple studies, expected capitalized cost of drug development estimates are highly sensitive to cost of capital and phase transition success probability assumptions. Our study uses a cost of capital of 11 percent whereas others use cost of capital figures ranging from 0 percent, 7 percent, and 10.5 percent.

Even small deviations in the cost of capital can result in significant swings in expected capitalized costs. For example, when the cost of capital is 11 percent, the expected capitalized cost (excluding post-approval study costs) for oncology drugs is $1,209.2 million (Table 11). If the cost of capital is reduced by half a percentage point to 10.5 percent, the estimated expected capitalized cost figure decreases to $1,170.6 million (a reduction of $38.6 million).

There also are differences in how therapeutic areas are defined across studies. For example, Wouters, et al (2020) group antineoplastic (i.e., anticancer) and immunomodulating agents together whereas this study considers them to be two distinct therapeutic areas (i.e., oncology and immunomodulation). Similarly, they group alimentary tract and metabolism drugs together whereas this study separates them into gastrointestinal and endocrine therapeutic areas. Finally, this study includes costs for FDA review (around $2.6 million) whereas the other studies do not incorporate these costs.

The projected estimates of overall cost savings from different strategies likely have large uncertainty bounds. First, these estimates reflect opinions of a relatively small group of experts; they are not based on controlled experiments (e.g., comparing the cost, duration, phase transition success probability of a sufficiently large sample of trials that use adaptive designs to those that do not). Numerous studies have shown that expert opinion could be biased and subject to high degree of variability. Second, the onerous nature of the expert elicitation did not allow for in-depth follow-up discussions to gain a better understanding of the mental models experts were using when thinking about the different strategies. For example, each expert might have had a different set of FDA guidance documents that could benefit from further clarity and/or consistency when evaluating the expected impact of FDA Review Process Efficiency and Interactions strategy. Additionally, experts did not account for the additional resource burden associated with implementation of such strategies nor policies that may already be in place but are not necessarily public knowledge (e.g., internal training programs for FDA reviewers, planned or ongoing updates to FDA guidances).