# 5 MODEL PARAMETERS AND ASSUMPTIONS

Table 2 presents the parameter estimates and assumptions for our drug development cost model. We discuss the basis for these estimates in the following sections. Because our model encompasses 13 different therapeutic areas, we generally address the overall average across all therapeutic areas, presented in the right-most column, in the below discussions for brevity.

Table 2 Summary of Drug Development Cost Model Parameters and Assumptions, by Therapeutic Area and Phase

Parameter | Phase | Anti-Infective | Cardiovascular | Central Nervous System | Dermatology | Endocrine | Gastrointestinal | Genitourinary System | Hematology | Oncology | Respiratory System | Ophthalmology | Pain and Anesthesia | Immunomodulation | All Therapeutic Areas
Start to Start (in Months) | Non-clinical to Phase 1 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2
Start to Start (in Months) | Phase 1 to Phase 2 | 12.9 | 8.5 | 11.7 | 16.6 | 7.7 | 16.6 | 7.4 | 14.2 | 19.1 | 10.5 | 10.7 | 16.6 | 7.9 | 16.6
Start to Start (in Months) | Phase 2 to Phase 3 | 22.4 | 30.4 | 32.1 | 27.2 | 23.4 | 27.2 | 20.6 | 28.0 | 32.2 | 29.7 | 21.6 | 27.2 | 26.5 | 27.2
Start to Start (in Months) | Phase 3 to FDA review | 22.3 | 28.6 | 30.8 | 25.9 | 24.2 | 25.9 | 22.4 | 39.7 | 39.3 | 28.7 | 22.9 | 25.9 | 24.7 | 25.9
Start to Start (in Months) | FDA BLA/NDA review to approval | 14.8 | 19.1 | 21.0 | 12.2 | 18.8 | 17.9 | 18.3 | 15.3 | 9.6 | 18.9 | 11.9 | 31.7 | 16.8 | 16.2
Phase Durations (in months) | Non-clinical | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2 | 31.2
Phase Durations (in months) | Phase 1 | 21.5 | 14.1 | 19.5 | 27.8 | 12.9 | 27.8 | 12.4 | 23.8 | 31.9 | 17.6 | 17.9 | 27.8 | 13.1 | 27.8
Phase Durations (in months) | Phase 2 | 28.0 | 38.0 | 40.1 | 34.0 | 29.3 | 34.0 | 25.8 | 35.0 | 40.3 | 37.1 | 27.0 | 34.0 | 33.1 | 34.0
Phase Durations (in months) | Phase 3 | 32.8 | 42.0 | 45.3 | 38.0 | 35.6 | 38.0 | 33.0 | 58.3 | 57.7 | 42.2 | 33.7 | 38.0 | 36.3 | 38.0
Phase Durations (in months) | FDA BLA/NDA review | 14.8 | 19.1 | 21.0 | 12.2 | 18.8 | 17.9 | 18.3 | 15.3 | 9.6 | 18.9 | 11.9 | 31.7 | 16.8 | 16.2
Phase Durations (in months) | Phase 4 | 38.7 | 38.5 | 35.0 | 36.6 | 34.0 | 36.6 | 29.9 | 36.6 | 45.7 | 36.6 | 30.7 | 36.6 | 39.6 | 36.6
Per-patient Cost (in $ 2018) | Non-clinical | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Per-patient Cost (in $ 2018) | Phase 1 | $19,399 | $59,456 | $87,390 | $35,450 | $85,463 | $61,848 | $53,770 | $349,363 | $103,344 | $44,330 | $50,999 | $90,370 | $63,471 | $81,338
Per-patient Cost (in $ 2018) | Phase 2 | $59,289 | $41,323 | $48,767 | $66,661 | $51,556 | $63,590 | $45,781 | $100,554 | $78,753 | $43,563 | $48,438 | $77,726 | $47,897 | $58,618
Per-patient Cost (in $ 2018) | Phase 3 | $30,001 | $33,084 | $39,612 | $48,587 | $48,753 | $47,656 | $38,930 | $118,473 | $93,145 | $46,764 | $79,933 | $60,751 | $54,909 | $53,180
Per-patient Cost (in $ 2018) | FDA BLA/NDA review | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Per-patient Cost (in $ 2018) | Phase 4 | $13,814 | $33,915 | $34,956 | $33,102 | $56,824 | $52,746 | $16,699 | $41,958 | $23,515 | $18,987 | $24,022 | $41,573 | $30,246 | $35,190
Number of Patients Enrolled per Trial | Non-clinical | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Number of Patients Enrolled per Trial | Phase 1 | 69 | 42 | 44 | 106 | 38 | 38 | 50 | 31 | 58 | 49 | 121 | 36 | 55 | 51
Number of Patients Enrolled per Trial | Phase 2 | 243 | 189 | 243 | 133 | 225 | 292 | 323 | 134 | 137 | 203 | 299 | 270 | 323 | 235
Number of Patients Enrolled per Trial | Phase 3 | 575 | 1,151 | 529 | 568 | 414 | 496 | 546 | 233 | 293 | 516 | 876 | 1,209 | 309 | 630
Number of Patients Enrolled per Trial | FDA BLA/NDA review | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Number of Patients Enrolled per Trial | Phase 4 | 1,430 | 508 | 356 | 850 | 482 | 1,344 | 410 | 411 | 261 | 1,159 | 413 | 280 | 383 | 708
Average Number of Trials | Non-clinical | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Average Number of Trials | Phase 1 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 2 | 1 | 1 | 1 | 2 | 2 | 2
Average Number of Trials | Phase 2 | 2 | 1 | 1 | 2 | 2 | 1 | 1 | 2 | 1 | 2 | 2 | 2 | 2 | 2
Average Number of Trials | Phase 3 | 2 | 2 | 3 | 3 | 4 | 2 | 1 | 2 | 2 | 4 | 2 | 3 | 3 | 3
Average Number of Trials | FDA BLA/NDA review | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA | NA
Average Number of Trials | Phase 4 | 2 | 2 | 2 | 1 | 2 | 2 | 1 | 2 | 1 | 2 | 2 | 1 | 2 | 2
Transition Success Probabilities (%) | Non-clinical to Phase 1 | 68.0% | 68.0% | 68.0% | 68.0% | 68.0% | 68.0% | 68.0% | 68.0% | 68.0% | 68.0% | 68.0% | 68.0% | 68.0% | 68.0%
Transition Success Probabilities (%) | Phase 1 to Phase 2 | 65.9% | 65.0% | 61.5% | 60.2% | 68.0% | 71.6% | 62.9% | 73.3% | 61.5% | 68.5% | 86.0% | 60.2% | 69.9% | 60.2%
Transition Success Probabilities (%) | Phase 2 to Phase 3 | 49.6% | 37.1% | 33.1% | 35.9% | 46.3% | 35.3% | 44.9% | 56.6% | 26.8% | 27.4% | 52.7% | 35.9% | 40.1% | 35.9%
Transition Success Probabilities (%) | Phase 3 to FDA review | 74.1% | 57.6% | 55.9% | 65.5% | 63.9% | 55.3% | 71.4% | 75.0% | 42.7% | 75.6% | 58.3% | 65.5% | 65.4% | 65.5%
Transition Success Probabilities (%) | FDA BLA/NDA review to approval | 94.4% | 75.5% | 87.0% | 88.3% | 81.3% | 86.2% | 85.7% | 84.0% | 85.5% | 89.5% | 77.5% | 88.3% | 95.3% | 88.3%
Out of Pocket Cost Estimates (in $ 2018 million) | Non-clinical | $9.4 | $10.1 | $8.7 | $9.3 | $14.2 | $11.4 | $7.7 | $17.9 | $7.0 | $9.0 | $32.0 | $22.2 | $11.6 | $11.8
Out of Pocket Cost Estimates (in $ 2018 million) | Phase 1 | $2.8 | $4.2 | $6.8 | $6.5 | $6.8 | $4.3 | $4.2 | $17.3 | $8.1 | $3.2 | $7.6 | $6.1 | $6.8 | $7.1
Out of Pocket Cost Estimates (in $ 2018 million) | Phase 2 | $22.3 | $11.2 | $16.1 | $14.9 | $19.4 | $26.2 | $19.8 | $22.1 | $14.5 | $13.7 | $22.8 | $34.6 | $24.3 | $21.0
Out of Pocket Cost Estimates (in $ 2018 million) | Phase 3 | $41.6 | $91.2 | $59.4 | $70.6 | $85.8 | $58.1 | $31.3 | $61.9 | $37.7 | $90.5 | $173.0 | $214.4 | $52.4 | $89.3
Out of Pocket Cost Estimates (in $ 2018 million) | FDA BLA/NDA review to approval | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6
Cost of Capital (%) | | 11.0%

NA = Not applicable

Note that all values are rounded up to the nearest whole number.

## 5.1 PHASE DURATIONS

The phase duration parameter refers to the time it takes to complete a given stage of development depicted in Figure 1. For the non-clinical stage, our estimate represents the time it takes from synthesis of the compound to the start of human trials, which includes early exploratory research for target discovery, hit generation and target identification; lead optimization; preclinical work involving animal testing to develop dosing and toxicity models; and obtaining an IND approval from FDA to begin testing in human subjects. We used published studies and information compiled from FDA’s DASH database to estimate average phase durations across all development stages (Table 3) by therapeutic area. From Table 3, Phase 3 is the longest (38.0 months) drug development stage across all therapeutic areas followed by post-approval Phase 4 (36.6 months), Phase 2 (34.0 months), non-clinical stage (31.2 months), and Phase 1 (27.8 months). The average time for the FDA review phase is 16.2 months. This includes the time the sponsor spends on responding to any questions and/or information requests from the FDA as well as preparing major/minor amendments, if needed. Thus, the estimate does not solely reflect the time FDA spends on reviewing the application. While there is variation in phase durations across the different therapeutic areas, this ranking is generally stable with Phase 3 comprising the longest stage and FDA review the shortest one.

## 5.2 TIME FROM PHASE START TO NEXT PHASE START

The start-to-start parameter refers to the elapsed time between the start of one development phase (e.g., Phase 2) and the start of the next development phase (e.g., Phase 3) supporting an application. For the non-clinical phase to Phase 1 estimate, we assumed that Phase 1 will begin immediately upon successful completion of the non-clinical development phase and receipt of IND approval from FDA. Similarly, for the FDA review to approval estimate, we used the estimates reported in Table 3 by therapeutic area (ranging from 9.6 months for oncology to 31.7 months for pain and anesthesia drugs). For the clinical phases, work on the clinical phases may overlap. In other words, the sponsor may begin Phase 2 clinical trials before completing the Phase 1 clinical trials. DiMasi et al. (2016) estimated the average phase duration, t_i_, and average time to next phase, t_i−j_, where i = 1, 2, 3, and j = 2, 3, FDA BLA/NDA review, for each of the three clinical phases as:

▪ t_1_ = 33.1 months; t_1−2_ = 19.8 months
▪ t_2_ = 37.9 months; t_2−3_ = 30.3 months
▪ t_3_ = 45.1 months; t_3−FDA BLA/NDA Review_ = 30.7 months

To estimate the average phase start to next phase start durations, we used the DiMasi et al. (2016) estimates along with our phase duration estimates. For example, the average Phase 1 length for the Anti-Infective therapeutic area is 21.5 months (Table 3). Then, we estimated the average time to Phase 2 as the product of estimated average Phase 1 length (21.5 months) and the ratio of average time to Phase 2 to average Phase 1 length (19.8 ÷ 33.1 months) as reported in DiMasi et al. (2016) at 12.9 months (= 21.5 × [19.8 ÷ 33.1] months).

Table 3 Average Phase Durations (in Months), by Therapeutic Area

Source | Time Period | Therapeutic Area | Therapeutic Area in the Original Source^[a]^ | Non-clinical | Phase 1 | Phase 2 | Phase 3 | FDA BLA/NDA Review | Phase 4
Wong et al (2019) | 2000-2015 | Anti-Infective | Infectious Disease | NA | 18.4 | 31.2 | 35.0 | NA | 38.7
BiomedTracker (2016) | 2006-2015 | Anti-Infective | Infectious Disease | NA | NA | NA | NA | 16.8 | NA
FDA DASH Query (2018l) | 2007-2017 | Anti-Infective | Anti-Infective | NA | NA | NA | NA | 12.9 | NA
Abrantes-Metz et al (2004) | 1989-2002 | Anti-Infective | Anti-HIV/AIDS | NA | 24.7 | 24.8 | 30.6 | NA | NA
Wong et al (2019) | 2000-2015 | Cardiovascular | Cardiovascular | NA | 12.4 | 33.6 | 39.6 | NA | 38.5
BiomedTracker (2016) | 2006-2015 | Cardiovascular | Cardiovascular | NA | NA | NA | NA | 16.8 | NA
FDA DASH Query (2018l) | 2007-2017 | Cardiovascular | Cardiovascular | NA | NA | NA | NA | 21.5 | NA
Abrantes-Metz et al (2004) | 1989-2002 | Cardiovascular | Anti-Hypertension | NA | 15.9 | 42.5 | 44.4 | NA | NA
Wong et al (2019) | 2000-2015 | Central Nervous System | Central Nervous System | NA | 11.0 | 30.6 | 33.9 | NA | 35.0
BiomedTracker (2016) | 2006-2015 | Central Nervous System | Neurology | NA | NA | NA | NA | 23.9 | NA
BiomedTracker (2016) | 2006-2015 | Central Nervous System | Psychiatry | NA | NA | NA | NA | 19.1 | NA
FDA DASH Query (2018l) | 2007-2017 | Central Nervous System | Central Nervous System | NA | NA | NA | NA | 19.8 | NA
Abrantes-Metz et al (2004) | 1989-2002 | Central Nervous System | Anti-Alzheimer’s Disease | NA | 23.2 | 46.9 | 41.8 | NA | NA
Abrantes-Metz et al (2004) | 1989-2002 | Central Nervous System | Anti-Parkinson’s Disease | NA | 24.4 | 42.9 | 60.1 | NA | NA
FDA DASH Query (2018l) | 2007-2017 | Dermatology | Dermatology | NA | NA | NA | NA | 12.2 | NA
Wong et al (2019) | 2000-2015 | Endocrine | Metabolic Diseases | NA | 10.7 | 31.0 | 32.0 | NA | 34.0
Wong et al (2019) | 2000-2015 | Endocrine | Endocrinology | NA | 10.7 | 31.0 | 32.0 | NA | 34.0
BiomedTracker (2016) | 2006-2015 | Endocrine | Metabolic Diseases | NA | NA | NA | NA | 18.0 | NA
BiomedTracker (2016) | 2006-2015 | Endocrine | Endocrinology | NA | NA | NA | NA | 21.5 | NA
FDA DASH Query (2018l) | 2007-2017 | Endocrine | Endocrine | NA | NA | NA | NA | 16.9 | NA
Abrantes-Metz et al (2004) | 1989-2002 | Endocrine | Anti-Diabetes | NA | 17.4 | 25.8 | 42.7 | NA | NA
BiomedTracker (2016) | 2006-2015 | Gastrointestinal | Gastroenterology | NA | NA | NA | NA | 21.5 | NA
FDA DASH Query (2018l) | 2007-2017 | Gastrointestinal | Gastrointestinal | NA | NA | NA | NA | 14.2 | NA
Wong et al (2019) | 2000-2015 | Genitourinary System | Genitourinary | NA | 12.4 | 25.8 | 33.0 | NA | 29.9
BiomedTracker (2016) | 2006-2015 | Genitourinary System | Urology | NA | NA | NA | NA | 20.4 | NA
FDA DASH Query (2018l) | 2007-2017 | Genitourinary System | Genitourinary System | NA | NA | NA | NA | 16.2 | NA
BiomedTracker (2016) | 2006-2015 | Hematology | Hematology | NA | NA | NA | NA | 19.1 | NA
FDA DASH Query (2018l) | 2007-2017 | Hematology | Hematology | NA | NA | NA | NA | 11.5 | NA
Abrantes-Metz et al (2004) | 1989-2002 | Hematology | Anti-Thrombosis | NA | 23.8 | 35.0 | 58.3 | NA | NA
Wong et al (2019) | 2000-2015 | Immunomodulation | Autoimmune Diseases | NA | 11.0 | 32.1 | 32.1 | NA | 39.6
Wong et al (2019) | 2000-2015 | Immunomodulation | Inflammation | NA | 11.0 | 32.1 | 32.1 | NA | 39.6
BiomedTracker (2016) | 2006-2015 | Immunomodulation | Autoimmune Diseases | NA | NA | NA | NA | 19.1 | NA
FDA DASH Query (2018l) | 2007-2017 | Immunomodulation | Immunomodulation | NA | NA | NA | NA | 14.5 | NA
Abrantes-Metz et al (2004) | 1989-2002 | Immunomodulation | Anti-Arthritis | NA | 17.5 | 35.1 | 44.8 | NA | NA
Wong et al (2019) | 2000-2015 | Oncology | Oncology | NA | 39.9 | 48.9 | 68.2 | NA | 45.7
BiomedTracker (2016) | 2006-2015 | Oncology | Oncology | NA | NA | NA | NA | 13.2 | NA
FDA DASH Query (2018l) | 2007-2017 | Oncology | Oncology | NA | NA | NA | NA | 5.9 | NA
Abrantes-Metz et al (2004) | 1989-2002 | Oncology | Anti-Cancer | NA | 23.8 | 31.7 | 47.1 | NA | NA
Wong et al (2019) | 2000-2015 | Ophthalmology | Ophthalmology | NA | 17.9 | 27.0 | 33.7 | NA | 30.7
BiomedTracker (2016) | 2006-2015 | Ophthalmology | Ophthalmology | NA | NA | NA | NA | 15.6 | NA
FDA DASH Query (2018l) | 2007-2017 | Ophthalmology | Ophthalmology | NA | NA | NA | NA | 8.3 | NA
FDA DASH Query (2018l) | 2007-2017 | Pain and Anesthesia | Pain and Anesthesia | NA | NA | NA | NA | 31.7 | NA
BiomedTracker (2016) | 2006-2015 | Respiratory System | Allergy | NA | NA | NA | NA | 15.6 | NA
BiomedTracker (2016) | 2006-2015 | Respiratory System | Respiratory | NA | NA | NA | NA | 19.1 | NA
FDA DASH Query (2018l) | 2007-2017 | Respiratory System | Respiratory System | NA | NA | NA | NA | 21.9 | NA
Abrantes-Metz et al (2004) | 1989-2002 | Respiratory System | Anti-Asthma | NA | 17.6 | 37.1 | 42.2 | NA | NA
Wong et al (2019) | 2000-2015 | All Therapeutic Areas | Overall | NA | 19.3 | 35.2 | 46.0 | NA | NA
BiomedTracker (2016) | 2006-2015 | All Therapeutic Areas | Overall | NA | NA | NA | NA | 19.1 | NA
FDA DASH Query (2018l) | 2007-2017 | All Therapeutic Areas | Overall | NA | NA | NA | NA | 13.6 | NA
Martin, Hutchens, & Hawkins (2017) | 2006-2008 | All Therapeutic Areas | Overall | NA | 30.9 | 32.9 | 32.9 | NA | NA
Martin, Hutchens, & Hawkins (2017) | 2007-2009 | All Therapeutic Areas | Overall | NA | 32.9 | 32.9 | 34.9 | NA | NA
Martin, Hutchens, & Hawkins (2017) | 2008-2010 | All Therapeutic Areas | Overall | NA | 30.9 | 33.9 | 34.9 | NA | NA
Martin, Hutchens, & Hawkins (2017) | 2009-2011 | All Therapeutic Areas | Overall | NA | 30.9 | 33.9 | 33.9 | NA | NA
Martin, Hutchens, & Hawkins (2017) | 2010-2012 | All Therapeutic Areas | Overall | NA | 27.0 | 34.9 | 36.9 | NA | NA
Martin, Hutchens, & Hawkins (2017) | 2011-2013 | All Therapeutic Areas | Overall | NA | 29.0 | 32.9 | 41.9 | NA | NA
Martin, Hutchens, & Hawkins (2017) | 2012-2014 | All Therapeutic Areas | Overall | NA | 30.9 | 35.9 | 40.9 | NA | NA
Martin, Hutchens, & Hawkins (2017) | 2013-2015 | All Therapeutic Areas | Overall | NA | 31.9 | 39.9 | 38.9 | NA | NA
DiMasi, Grabowski, Hansen, (2016) | NA | All Therapeutic Areas | Overall | 31.2 | 19.8 | 30.3 | 30.7 | 16.0 | NA
Abrantes-Metz et al (2004) | 1989-2002 | All Therapeutic Areas | Overall | NA | 22.0 | 31.6 | 45.9 | NA | NA
Anti-Infective Average | | | | 31.2 ^[b]^ | 21.5 | 28.0 | 32.8 | 14.8 | 38.7
Cardiovascular Average | | | | 31.2 ^[b]^ | 14.1 | 38.0 | 42.0 | 19.1 | 38.5
Central Nervous System Average | | | | 31.2 ^[b]^ | 19.5 | 40.1 | 45.3 | 21.0 | 35.0
Dermatology Average | | | | 31.2 ^[b]^ | 27.8 ^[b]^ | 34.0 ^[b]^ | 38.0 ^[b]^ | 12.2 | 36.6 ^[b]^
Endocrine Average | | | | 31.2 ^[b]^ | 12.9 | 29.3 | 35.6 | 18.8 | 34.0
Gastrointestinal Average | | | | 31.2 ^[b]^ | 27.8 ^[b]^ | 34.0 ^[b]^ | 38.0 ^[b]^ | 17.9 | 36.6 ^[b]^
Genitourinary System Average | | | | 31.2 ^[b]^ | 12.4 | 25.8 | 33.0 | 18.3 | 29.9
Hematology Average | | | | 31.2 ^[b]^ | 23.8 | 35.0 | 58.3 | 15.3 | 36.6 ^[b]^
Oncology Average | | | | 31.2 ^[b]^ | 31.9 | 40.3 | 57.7 | 9.6 | 45.7
Respiratory System Average | | | | 31.2 ^[b]^ | 17.6 | 37.1 | 42.2 | 18.9 | 36.6
Ophthalmology Average | | | | 31.2 ^[b]^ | 17.9 | 27.0 | 33.7 | 11.9 | 30.7
Pain and Anesthesia Average | | | | 31.2 ^[b]^ | 27.8 ^[b]^ | 34.0 ^[b]^ | 38.0 ^[b]^ | 31.7 | 36.6 ^[b]^
Immunomodulation Average | | | | 31.2 ^[b]^ | 13.1 | 33.1 | 36.3 | 16.8 | 39.6
All Therapeutic Areas Average | | | | 31.2 ^[b]^ | 27.8 | 34.0 | 38.0 | 16.2 | 36.6] ^[c]^

NA = Not available

[a] This represents the therapeutic area or disease for which the duration estimates correspond to in the original source. We mapped these reported therapeutic areas and/or diseases to the therapeutic areas in this model.

[b] The figure is the All Therapeutic Areas average duration as no information was available for the therapeutic area and phase combination.

[c] This represents the average across all estimates in the table from Anti-infective through Immunomodulation therapeutic areas.

As can be observed from Table 2, there is overlap between successive stages of clinical development. For example, sponsors begin Phase 2 studies on a larger cohort of patients with more diverse conditions when initial safety and dosing results from Phase 1 studies are available even if those studies may not be fully complete. Thus, even though a Phase 1 study is estimated to last around 27.8 months on average across all therapeutic areas, a sponsor may begin a Phase 2 study on average 16.6 months after initiating the associated Phase 1 study.

## 5.3 AVERAGE NUMBER OF PATIENTS ENROLLED PER TRIAL

Number of patients enrolled in a study is the largest single factor driving study costs (Moore, et al., 2020). We used three databases (Medidata, clinicaltrials.gov, and FDA DASH), of which FDA DASH and Medidata are non-public, to estimate the average number of patients enrolled per trial by therapeutic area and phase (Table 4). The databases used cover different periods and vary in sample size, i.e., number of studies included. Ideally, the average number of patients enrolled estimate should be based on recent trials (preferably in the last 5 years) conducted in support of an NDA or BLA submission to FDA and rely on a large number of trials for each therapeutic area. None of the three databases satisfy these criteria fully. For example, Medidata database includes large number of studies, but it covers studies from 2004 through 2012 and includes trials that are not conducted in support of an NDA or BLA application to FDA. Similar to Medidata, clinicaltrials.gov database has a large number of studies from 2014 through June 2020 but also includes those that are not conducted in support of an NDA or BLA. On the other hand, FDA DASH database includes information from more recent trials (2007 through 2017) that are conducted in support of an FDA application but has fewer studies^8^ and does not include data on Phase 1 or Phase 4 trials or those trials that failed. Thus, we used all three databases to calculate the weighted average number of patients enrolled by therapeutic area and phase where the weights are the number of studies in each database.

Given the proprietary nature of information used, Table 4 only depicts the weighted mean number of patients per trial by therapeutic area estimated, where the weights are the number of studies in each data source relative to the total number of studies across all sources.

From Table 4, the weighted average number of patients per trial across different therapeutic areas are highly variable. For Phase 1, the weighted average ranges from 31 patients for hematology to 121 for ophthalmology trials; 133 for dermatology to 323 immunomodulation trials for Phase 2; 233 for hematology to 1,209 for pain and anesthesia trials for Phase 3; and 261 for oncology to 1,430 for anti-infective trials for Phase 4. Across all therapeutic areas, the weighted average number of patients enrolled per trial is 51 for Phase 1, 235 for Phase 2, 630 for Phase 3, and 708 for Phase 4.

Table 4 Average Number of Patients per Trial, by Therapeutic Area

Therapeutic Area | Phase | Weighted Average Number of Patients per Trial
Anti-Infective | Phase 1 | 69
Anti-Infective | Phase 2 | 243
Anti-Infective | Phase 3 | 575
Anti-Infective | Phase 4 | 1,430
Cardiovascular | Phase 1 | 42
Cardiovascular | Phase 2 | 189
Cardiovascular | Phase 3 | 1,151
Cardiovascular | Phase 4 | 508
Central Nervous System | Phase 1 | 44
Central Nervous System | Phase 2 | 243
Central Nervous System | Phase 3 | 529
Central Nervous System | Phase 4 | 356
Dermatology | Phase 1 | 106
Dermatology | Phase 2 | 133
Dermatology | Phase 3 | 568
Dermatology | Phase 4 | 850
Endocrine | Phase 1 | 38
Endocrine | Phase 2 | 225
Endocrine | Phase 3 | 414
Endocrine | Phase 4 | 482
Gastrointestinal | Phase 1 | 38
Gastrointestinal | Phase 2 | 292
Gastrointestinal | Phase 3 | 496
Gastrointestinal | Phase 4 | 1,344
Genitourinary System | Phase 1 | 50
Genitourinary System | Phase 2 | 323
Genitourinary System | Phase 3 | 546
Genitourinary System | Phase 4 | 410
Hematology | Phase 1 | 31
Hematology | Phase 2 | 134
Hematology | Phase 3 | 233
Hematology | Phase 4 | 411
Immunomodulation | Phase 1 | 55
Immunomodulation | Phase 2 | 323
Immunomodulation | Phase 3 | 309
Immunomodulation | Phase 4 | 383
Oncology | Phase 1 | 58
Oncology | Phase 2 | 137
Oncology | Phase 3 | 293
Oncology | Phase 4 | 261
Ophthalmology | Phase 1 | 121
Ophthalmology | Phase 2 | 299
Ophthalmology | Phase 3 | 876
Ophthalmology | Phase 4 | 413
Pain and Anesthesia | Phase 1 | 36
Pain and Anesthesia | Phase 2 | 270
Pain and Anesthesia | Phase 3 | 1,209
Pain and Anesthesia | Phase 4 | 280
Respiratory System | Phase 1 | 49
Respiratory System | Phase 2 | 203
Respiratory System | Phase 3 | 516
Respiratory System | Phase 4 | 1,159
All Therapeutic Areas | Phase 1 | 51
All Therapeutic Areas | Phase 2 | 235
All Therapeutic Areas | Phase 3 | 630
All Therapeutic Areas | Phase 4 | 708

Further, within several therapeutic area and phase combinations, the variation across the average number of patients reported in the different databases is also significant. For example, the average number of patients in Phase 3 cardiovascular trials in FDA DASH is over nine times larger than that estimated from clinicaltrials.gov and over five times larger than that estimated from Medidata. However, there are a few therapeutic area and phase combinations for which this variation is minimal, such as Phase 2 and Phase 3 dermatology trials.

## 5.4 AVERAGE NUMBER OF TRIALS CONDUCTED IN SUPPORT OF AN FDA NDA/BLA APPLICATION

Sponsors indicate whether a trial is associated with an IND when they register it in clinicaltrials.gov. However, this information is only available to the National Institutes of Health (NIH) and the FDA, not to the general public. Thus, we requested a custom data pull from FDA CDER to estimate the average number of trials per IND application. FDA’s internal tracking system allows drug application reviewers to select from over 800 IND Division Class Codes (Tier 3), which are mapped onto 43 broader (Tier 1) division class categories. We mapped our therapeutic areas to these 43 FDA categories and FDA CDER compiled the number of INDs and IND-linked clinical trials by these therapeutic areas and phase. Next, FDA CDER calculated the average number of trials by therapeutic area and phase by dividing the clinical trial counts for a given phase and therapeutic area by the unique IND counts for the same phase and therapeutic area. FDA CDER’s (2019d) estimates are provided in Table 5.

From Table 5, the average number of trials conducted in support of an FDA application for a new drug is 1.71 for Phase 1, 1.52 for Phase 2, 2.66 for Phase 3, and 1.64 for Phase 4 across all therapeutic areas. For most therapeutic areas, sponsors conduct more than the two required Phase 3 trials with some running over four (endocrine) Phase 3 trials.

Table 5 Average Number of Trials Conducted in Support of an FDA NDA/BLA Application, by Therapeutic Area and Phase

Therapeutic Area | Phase 1 | Phase 2 | Phase 3 | Phase 4
Anti-Infective | 2.06 | 1.55 | 2.41 | 1.55
Cardiovascular | 1.65 | 1.43 | 2.40 | 1.99
Central Nervous System | 1.77 | 1.36 | 2.83 | 1.56
Dermatology | 1.74 | 1.69 | 2.56 | 1.42
Endocrine | 2.11 | 1.67 | 4.25 | 1.91
Gastrointestinal | 1.81 | 1.41 | 2.46 | 1.61
Genitourinary System | 1.58 | 1.34 | 1.47 | 1.00
Hematology | 1.62 | 1.63 | 2.37 | 1.59
Immunomodulation | 1.96 | 1.57 | 3.09 | 1.86
Oncology | 1.36 | 1.34 | 1.63 | 1.29
Ophthalmology | 1.23 | 1.57 | 2.47 | 1.83
Pain and Anesthesia | 1.90 | 1.65 | 2.92 | 1.49
Respiratory System | 1.46 | 1.55 | 3.75 | 2.22
All Therapeutic Areas | 1.71 | 1.52 | 2.66 | 1.64

Source: FDA CDER, (2019d)

[a] Data are current as of 7/23/2019.

[b] Excludes INDs received by CDER prior to the establishment of clinicaltrials.gov.

[c] Excludes trials not conducted under an IND.

[d] Excludes trials not registered with clinicaltrials.gov.

[e] Excludes trials associated with INDs not having a Division Classification Code.

[f] Excludes trials associated with INDs having a Division Classification Code that was not mapped to any of the therapeutic areas included in this model

[g] Division Classification Codes have not undergone quality control to ensure accuracy.

[h] The figures are calculated by dividing the number of trials for a given therapeutic area and phase by a distinct count of IND(s) associated with the corresponding cohort of trials (within the same therapeutic area and phase).

## 5.5 AVERAGE COST PER PATIENT

The total cost of a clinical trial for a given phase and therapeutic area, C_total_, includes study-level costs (such as institutional review board approvals and source data verification costs), C_study_, patient-level costs (such as recruitment and clinical procedure costs), C_patient_, and site-level costs (such as monitoring and project management), C_site_ (Sertkaya, et al., 2016), i.e.:

C_t o t a l_ = C_s t u d y_ + C_p a t i e n t_ + C_s i t e_ Equation 9. The total cost, denoted C sub total, equals C sub study plus C sub patient plus C sub site. (9)

Then, the average cost per-patient, CPP, can be calculated by dividing the total cost of a clinical trial C_total_, by the number of patients, n_patient_, enrolled in that trial, i.e.:

C P P = (C_t o t a l_)/(n_p a t i e n t_) Equation 10. CPP equals the total cost, denoted C sub total, divided by the number of patients, denoted n sub patient. (10)

We used three different data sources to estimate the average cost per patient. Two of the data sources (Cutting Edge and Medidata) included data on total clinical trial costs and the number of patients enrolled which allowed us to directly estimate the average cost per patient using the above equation. The third source, IQVIA, only contained information on patient-level costs, which comprise between 10 to 70 percent of total trial costs depending on therapeutic area and phase according to information available from the Medidata database. For comparability, we adjusted the reported IQVIA patient-level costs by these percentages. For example, if IQVIA reported a patient level cost of $10,000 for a Phase 1 study and patient-level costs were estimated to be around 20 percent of total costs in Medidata for that therapeutic area, we estimated the IQVIA average cost per patient at $50,000 (= $10,000 ÷ 0.20). The approach assumes that the shares of study, patient, and site costs for IQVIA are equivalent to those in Medidata. Due to the proprietary nature of these databases, we only present the weighted average cost per patient estimates by therapeutic area and phase in Table 6, where the weights are the number of studies in each database. As expected, the average cost per patient varies significantly by therapeutic area; $19,399 (anti-infective) to $349,363 (hematology) for Phase 1, $41,323 (cardiovascular) to $100,554 (hematology) for Phase 2, $30,001 (anti-infective) to $118,473 (hematology) for Phase 3, and $13,814 (anti-infective) to $56,824 (endocrine) for Phase 4. Across all therapeutic areas, the average cost per patient is $81,338 for Phase 1, $58,618 for Phase 2, $53,180 for Phase 3, and $35,190 for Phase 4 trials.

Table 6 Average Per-patient Costs (in 2018 $), by Therapeutic Area and Phase

Therapeutic Area | Phase | Weighted Average
Anti-Infective | Phase 1 | $19,399
Anti-Infective | Phase 2 | $59,289
Anti-Infective | Phase 3 | $30,001
Anti-Infective | Phase 4 | $13,814
Cardiovascular | Phase 1 | $59,456
Cardiovascular | Phase 2 | $41,323
Cardiovascular | Phase 3 | $33,084
Cardiovascular | Phase 4 | $33,915
Central Nervous System | Phase 1 | $87,390
Central Nervous System | Phase 2 | $48,767
Central Nervous System | Phase 3 | $39,612
Central Nervous System | Phase 4 | $34,956
Dermatology | Phase 1 | $35,450
Dermatology | Phase 2 | $66,661
Dermatology | Phase 3 | $48,587
Dermatology | Phase 4 | $33,102
Endocrine | Phase 1 | $85,463
Endocrine | Phase 2 | $51,556
Endocrine | Phase 3 | $48,753
Endocrine | Phase 4 | $56,824
Gastrointestinal | Phase 1 | $61,848
Gastrointestinal | Phase 2 | $63,590
Gastrointestinal | Phase 3 | $47,656
Gastrointestinal | Phase 4 | $52,746
Genitourinary System | Phase 1 | $53,770
Genitourinary System | Phase 2 | $45,781
Genitourinary System | Phase 3 | $38,930
Genitourinary System | Phase 4 | $16,699
Hematology ^[a]^ | Phase 1 | $349,363
Hematology ^[a]^ | Phase 2 | $100,554
Hematology ^[a]^ | Phase 3 | $118,473
Hematology ^[a]^ | Phase 4 | $41,958
Immunomodulation | Phase 1 | $63,471
Immunomodulation | Phase 2 | $47,897
Immunomodulation | Phase 3 | $54,909
Immunomodulation | Phase 4 | $30,246
Oncology | Phase 1 | $103,344
Oncology | Phase 2 | $78,753
Oncology | Phase 3 | $93,145
Oncology | Phase 4 | $23,515
Ophthalmology | Phase 1 | $50,999
Ophthalmology | Phase 2 | $48,438
Ophthalmology | Phase 3 | $79,933
Ophthalmology | Phase 4 | $24,022
Pain and Anesthesia | Phase 1 | $90,370
Pain and Anesthesia | Phase 2 | $77,726
Pain and Anesthesia | Phase 3 | $60,751
Pain and Anesthesia | Phase 4 | $41,573
Respiratory System | Phase 1 | $44,330
Respiratory System | Phase 2 | $43,563
Respiratory System | Phase 3 | $46,764
Respiratory System | Phase 4 | $18,987
All Therapeutic Areas | Phase 1 | $81,338
All Therapeutic Areas | Phase 2 | $58,618
All Therapeutic Areas | Phase 3 | $53,180
All Therapeutic Areas | Phase 4 | $35,190

[a] The representativeness of this category is highly limited due to small sample sizes and the types of indications covered in the included trials.

## 5.6 PHASE TRANSITION SUCCESS PROBABILITIES

The phase transition success probability parameter represents the probability of a sponsor successfully moving from one stage of drug development to the next. If, for example, out of 100 new drug candidates that make it to Phase 1, 30 successfully proceed to Phase 2, then the phase transition probability from Phase 1 to Phase 2 is 30 percent. We used published studies to estimate the average phase transition success probabilities (Table 7). Across all therapeutic areas, successfully transitioning from Phase 2 to Phase 3 generally has the lowest likelihood at 35.9 percent (ranging from 27.4 percent for respiratory system to 56.6 percent for hematology). Getting approval from the FDA for a new drug that has cleared Phase 3 has on average 88.3 percent likelihood across all therapeutic areas. Further, only 8.5 percent (= 0.68 × 0.602 × 0.359 × 0.655 × 0.883) of new drug candidates successfully move from non-clinical development to market. However, as the drug candidate successfully clears each successive development stage, the odds of making it to market improve. As expected, there is variation in this likelihood across therapeutic areas with hematology drugs having the highest likelihood at 17.8 percent and oncology drugs having the lowest likelihood at 4.1 percent (not shown).

Table 7 Transition Success Probabilities, by Therapeutic Area and Phase

Data Source | Time Period | Therapeutic Area | Therapeutic Area in the Original Source ^[a]^ | Other Classification | Nonclinical to Phase 1 | Phase 1 to Phase 2 | Phase 2 to Phase 3 | Phase 3 to FDA Review | FDA Review to Approval
Wong et al (2019) | 2000-2015 | Anti-Infective | Infectious Disease | NA | NA | 70.1% | 58.3% | NA | NA
DiMasi et al (2010) | 1993-2004 | Anti-Infective | Systemic Anti-infective | NA | NA | 58.2% | 52.2% | 78.6% | 100.0%
BiomedTracker (2016) | 2006-2015 | Anti-Infective | Infectious Disease | NA | NA | 69.5% | 42.7% | 72.7% | 88.7%
BiomedTracker, 2017 ^[c]^ | 2010-2016 | Anti-Infective | Infectious Disease | NA | NA | NA | 45.0% | 71.0% | NA
Wong et al (2019) | 2000-2015 | Cardiovascular | Cardiovascular | NA | NA | 73.3% | 65.7% | NA | NA
DiMasi et al (2010) | 1993-2004 | Cardiovascular | Cardiovascular | NA | NA | 62.9% | 32.4% | 64.3% | 66.7%
BiomedTracker (2016) | 2006-2015 | Cardiovascular | Cardiovascular | NA | NA | 58.9% | 24.1% | 55.5% | 84.2%
BiomedTracker, 2017 ^[c]^ | 2010-2016 | Cardiovascular | Cardiovascular | NA | NA | NA | 26.0% | 53.0% | NA
Wong et al (2019) | 2000-2015 | Central Nervous System | Central Nervous System | NA | NA | 73.2% | 51.9% | NA | NA
DiMasi et al (2010) | 1993-2004 | Central Nervous System | Central Nervous System | NA | NA | 59.6% | 33.0% | 46.4% | 90.0%
BiomedTracker (2016) | 2006-2015 | Central Nervous System | Neurology | NA | NA | 59.1% | 29.7% | 57.4% | 83.2%
BiomedTracker (2016) | 2006-2015 | Central Nervous System | Psychiatry | NA | NA | 53.9% | 23.7% | 55.7% | 87.9%
BiomedTracker, 2017 ^[c]^ | 2010-2016 | Central Nervous System | Neurology | NA | NA | NA | 33.0% | 60.0% | NA
BiomedTracker, 2017 ^[c]^ | 2010-2016 | Central Nervous System | Psychiatry | NA | NA | NA | 27.0% | 60.0% | NA
Wong et al (2019) | 2000-2015 | Endocrine | Metabolic Diseases | NA | NA | 76.2% | 59.7% | NA | NA
Wong et al (2019) | 2000-2015 | Endocrine | Endocrinology | NA | NA | 76.2% | 59.7% | NA | NA
DiMasi et al (2010) | 1993-2004 | Endocrine | Gastroenterology/Metabolism | NA | NA | 67.5% | 34.9% | 50.0% | 80.0%
BiomedTracker (2016) | 2006-2015 | Endocrine | Metabolic Diseases | NA | NA | 61.1% | 45.2% | 71.4% | 77.8%
BiomedTracker (2016) | 2006-2015 | Endocrine | Endocrinology | NA | NA | 58.9% | 40.1% | 65.0% | 86.0%
BiomedTracker, 2017 ^[c]^ | 2010-2016 | Endocrine | Endocrinology | NA | NA | NA | 38.0% | 69.0% | NA
DiMasi et al (2010) | 1993-2004 | Gastrointestinal | Gastroenterology/Metabolism | NA | NA | 67.5% | 34.9% | 50.0% | 80.0%
BiomedTracker (2016) | 2006-2015 | Gastrointestinal | Gastroenterology | NA | NA | 75.6% | 35.7% | 60.6% | 92.3%
Wong et al (2019) | 2000-2015 | Genitourinary System | Genitourinary | NA | NA | 68.7% | 57.1% | NA | NA
BiomedTracker (2016) | 2006-2015 | Genitourinary System | Urology | NA | NA | 57.1% | 32.7% | 71.4% | 85.7%
BiomedTracker (2016) | 2006-2015 | Hematology | Hematology | NA | NA | 73.3% | 56.6% | 75.0% | 84.0%
Wong et al (2019) | 2000-2015 | Immunomodulation | Autoimmune Diseases | NA | NA | 69.8% | 45.7% | NA | NA
Wong et al (2019) | 2000-2015 | Immunomodulation | Inflammation | NA | NA | 69.8% | 45.7% | NA | NA
DiMasi et al (2010) | 1993-2004 | Immunomodulation | Antineoplastic/immunologic | NA | NA | 71.8% | 49.0% | 55.3% | 100.0%
DiMasi et al (2010) | 1993-2004 | Immunomodulation | Musculoskeletal | NA | NA | 72.4% | 35.2% | 80.0% | 100.0%
BiomedTracker (2016) | 2006-2015 | Immunomodulation | Autoimmune Diseases | NA | NA | 65.7% | 31.7% | 62.2% | 86.0%
BiomedTracker, 2017 | 2010-2016 | Immunomodulation | Autoimmune Diseases | NA | NA | NA | 33.0% | 64.0% | NA
Wong et al (2019) | 2000-2015 | Oncology | Oncology | NA | NA | 57.6% | 32.7% | NA | NA
DiMasi et al (2010) | 1993-2004 | Oncology | Antineoplastic/immunologic | NA | NA | 71.8% | 49.0% | 55.3% | 100.0%
BiomedTracker (2016) | 2006-2015 | Oncology | Oncology | NA | NA | 62.8% | 24.6% | 40.1% | 82.4%
BiomedTracker (2016) | 2006-2015 | Oncology | Solid Tumors | NA | NA | 64.1% | 23.0% | 34.2% | 79.6%
BiomedTracker (2016) | 2006-2015 | Oncology | Hematological Cancers | NA | NA | 61.8% | 28.7% | 52.6% | 86.4%
BiomedTracker, 2017 ^[c]^ | 2010-2016 | Oncology | Oncology | NA | NA | NA | 27.0% | 45.0% | NA
Pharma Intelligence, Informa, 2016 ^[c]^ | 2011-2015 | Oncology | Oncology | NA | NA | 59.0% | 21.0% | 38.0% | 84.0%
Pharma Intelligence, Informa, 2016 ^[c]^ | 2011-2015 | Oncology | Solid Tumors | NA | NA | 57.0% | 20.0% | 32.0% | 83.0%
Pharma Intelligence, Informa, 2016 ^[c]^ | 2011-2015 | Oncology | Hematological Cancers | NA | NA | 64.0% | 26.0% | 54.0% | 84.0%
Pharma Intelligence, Informa, 2016 ^[c]^ | 2011-2015 | Oncology | Oncology | NME | NA | 56.0% | 18.0% | 36.0% | 77.0%
Pharma Intelligence, Informa, 2016 ^[c]^ | 2011-2015 | Oncology | Oncology | Large Molecule | NA | 61.0% | 25.0% | 40.0% | 93.0%
Wong et al (2019) | 2000-2015 | Ophthalmology | Ophthalmology | NA | NA | 87.1% | 60.7% | NA | NA
BiomedTracker (2016) | 2006-2015 | Ophthalmology | Ophthalmology | NA | NA | 84.8% | 44.6% | 58.3% | 77.5%
DiMasi et al (2010) | 1993-2004 | Respiratory System | Respiratory | NA | NA | 72.5% | 20.0% | 85.7% | 80.0%
BiomedTracker (2016) | 2006-2015 | Respiratory System | Allergy | NA | NA | 67.6% | 32.5% | 71.4% | 93.8%
BiomedTracker (2016) | 2006-2015 | Respiratory System | Respiratory | NA | NA | 65.3% | 29.1% | 71.1% | 94.6%
BiomedTracker, 2017 ^[c]^ | 2010-2016 | Respiratory System | Respiratory | NA | NA | NA | 28.0% | 74.0% | NA
Wong et al (2019) | 2000-2015 | All Therapeutic Areas | Overall | NA | NA | 66.4% | 58.3% | NA | NA
DiMasi et al (2010) | 1993-1998 | All Therapeutic Areas | Overall | NA | NA | 67.0% | 41.0% | 63.0% | 90.0%
DiMasi et al (2010) | 1999-2004 | All Therapeutic Areas | Overall | NA | NA | 64.0% | 39.0% | 66.0% | 100.0%
DiMasi et al (2010) | 1993-2004 | All Therapeutic Areas | Overall | Self-originated | NA | 65.0% | 40.0% | 64.0% | 93.0%
DiMasi et al (2010) | 1993-2004 | All Therapeutic Areas | Overall | Licensed-in | NA | 82.0% | 56.0% | 64.0% | 93.0%
DiMasi et al (2010) | 1993-2004 | All Therapeutic Areas | Overall | NA | NA | 71.0% | 45.0% | 64.0% | 93.0%
DiMasi et al (2010) | 1993-2004 | All Therapeutic Areas | Overall | Small Molecule | NA | 63.0% | 38.0% | 61.0% | 91.0%
DiMasi et al (2010) | 1993-2004 | All Therapeutic Areas | Overall | Large Molecule | NA | 84.0% | 53.0% | 74.0% | 96.0%
DiMasi et al (2010) | 1995-2007 | All Therapeutic Areas | Overall | NA | NA | 59.5% | 35.5% | 62.0% | 90.4%
BiomedTracker (2016) | 2006-2015 | All Therapeutic Areas | Overall | NA | NA | 63.2% | 30.7% | 58.1% | 85.3%
BiomedTracker (2016) | 2006-2015 | All Therapeutic Areas | Overall | NME | NA | 61.3% | 26.5% | 48.7% | 78.0%
BiomedTracker (2016) | 2006-2015 | All Therapeutic Areas | Overall | Large Molecule | NA | 66.0% | 34.4% | 57.2% | 88.4%
BiomedTracker (2016) | 2006-2015 | All Therapeutic Areas | Overall | Non-NME | NA | 70.1% | 48.3% | 73.9% | 90.4%
BiomedTracker (2016) | 2006-2015 | All Therapeutic Areas | Chronic High Prevalence Diseases | NA | NA | 58.7% | 27.7% | 61.6% | 87.2%
BiomedTracker (2016) | 2006-2015 | All Therapeutic Areas | Rare Diseases | NA | NA | 76.0% | 50.6% | 73.6% | 89.2%
KMR Bernstein Analysis, 2016 ^[c]^ | 2003-2007 | All Therapeutic Areas | Overall | NA | 69.0% | 54.0% | 34.0% | 70.0% | 91.0%
KMR Bernstein Analysis, 2016 ^[c]^ | 2005-2009 | All Therapeutic Areas | Overall | NA | 64.0% | 48.0% | 25.0% | 67.0% | 83.0%
KMR Bernstein Analysis, 2016 ^[c]^ | 2007-2011 | All Therapeutic Areas | Overall | NA | 64.0% | 44.0% | 22.0% | 65.0% | 83.0%
KMR Bernstein Analysis, 2016 ^[c]^ | 2007-2011 | All Therapeutic Areas | Overall | Small Molecule | 61.0% | 42.0% | 18.0% | 60.0% | 85.0%
KMR Bernstein Analysis, 2016 ^[c]^ | 2007-2011 | All Therapeutic Areas | Overall | Large Molecule | 75.0% | 56.0% | 44.0% | 79.0% | 79.0%
KMR Bernstein Analysis, 2016 ^[c]^ | 2010-2014 | All Therapeutic Areas | Overall | NA | 67.0% | 44.0% | 29.0% | 69.0% | 88.0%
KMR Bernstein Analysis, 2016 ^[c]^ | 2010-2014 | All Therapeutic Areas | Overall | Small Molecule | 62.0% | 40.0% | 24.0% | 65.0% | 90.0%
KMR Bernstein Analysis, 2016 ^[c]^ | 2010-2014 | All Therapeutic Areas | Overall | Large Molecule | 76.0% | 53.0% | 40.0% | 79.0% | 86.0%
KMR Bernstein Analysis, 2016 ^[c]^ | 2011-2015 | All Therapeutic Areas | Overall | NA | 68.0% | 45.0% | 33.0% | 77.0% | 92.0%
KMR Bernstein Analysis, 2016 ^[c]^ | 2011-2015 | All Therapeutic Areas | Overall | Small Molecule | 63.0% | 41.0% | 30.0% | 72.0% | 92.0%
KMR Bernstein Analysis, 2016 ^[c]^ | 2011-2015 | All Therapeutic Areas | Overall | Large Molecule | 79.0% | 52.0% | 39.0% | 88.0% | 93.0%
BiomedTracker, 2017 ^[c]^ | 2011 | All Therapeutic Areas | Overall | NA | NA | 64.0% | 32.0% | 60.0% | 83.0%
BiomedTracker, 2017 ^[c]^ | 2012 | All Therapeutic Areas | Overall | NA | NA | 65.0% | 33.0% | 61.0% | 85.0%
BiomedTracker, 2017 ^[c]^ | 2013 | All Therapeutic Areas | Overall | NA | NA | 64.0% | 32.0% | 60.0% | 86.0%
BiomedTracker, 2017 ^[c]^ | 2014 | All Therapeutic Areas | Overall | NA | NA | 65.0% | 33.0% | 62.0% | 87.0%
BiomedTracker, 2017 ^[c]^ | 2015 | All Therapeutic Areas | Overall | NA | NA | 64.0% | 32.0% | 61.0% | 87.0%
BiomedTracker, 2017 ^[c]^ | 2016 | All Therapeutic Areas | Overall | NA | NA | 65.0% | 33.0% | 60.0% | 88.0%
BiomedTracker, 2017 ^[c]^ | 2016 | All Therapeutic Areas | Overall | NME | NA | 62.0% | 28.0% | 51.0% | 83.0%
Anti-Infective Average | | | | | 68.0% ^[b]^ | 65.9% | 49.6% | 74.1% | 94.4%
Cardiovascular Average | | | | | 68.0% ^[b]^ | 65.0% | 37.1% | 57.6% | 75.5%
Central Nervous System Average | | | | | 68.0% ^[b]^ | 61.5% | 33.1% | 55.9% | 87.0%
Dermatology Average | | | | | 68.0% ^[b]^ | 60.2% ^[b]^ | 35.9% ^[b]^ | 65.5% ^[b]^ | 88.3% ^[b]^
Endocrine Average | | | | | 68.0% ^[b]^ | 68.0% | 46.3% | 63.9% | 81.3%
Gastrointestinal Average | | | | | 68.0% ^[b]^ | 71.6% | 35.3% | 55.3% | 86.2%
Genitourinary System Average | | | | | 68.0% ^[b]^ | 62.9% | 44.9% | 71.4% | 85.7%
Hematology Average | | | | | 68.0% ^[b]^ | 73.3% | 56.6% | 75.0% | 84.0%
Oncology Average | | | | | 68.0% ^[b]^ | 61.5% | 26.8% | 42.7% | 85.5%
Respiratory System Average | | | | | 68.0% ^[b]^ | 68.5% | 27.4% | 75.6% | 89.5%
Ophthalmology Average | | | | | 68.0% ^[b]^ | 86.0% | 52.7% | 58.3% | 77.5%
Pain and Anesthesia Average | | | | | 68.0% ^[b]^ | 60.2% ^[b]^ | 35.9% ^[b]^ | 65.5% ^[b]^ | 88.3% ^[b]^
Immunomodulation Average | | | | | 68.0% ^[b]^ | 69.9% | 40.1% | 65.4% | 95.3%
All Therapeutic Areas Average | | | | | 68.0% ^[b]^ | 60.2% | 35.9% | 65.5% | 88.3%

NA = Not available/Not applicable

[a] This represents the therapeutic area or disease for which the duration estimates correspond to in the original source. We mapped these reported therapeutic areas and/or diseases to the therapeutic areas in this model.

[b] The figure is the All Therapeutic Areas average transition probability as no information was available for the therapeutic area and phase-to-phase combination.

[c] From PAREXEL’s biopharmaceutical R&D statistical yearbook (PAREXEL International Corp., 2017).

## 5.7 OPPORTUNITY COST OF CAPITAL

The opportunity cost of capital (OCOC) represents the rate of return (net of inflation) that the sponsor would otherwise be able to earn at the same risk level as the investment in the new drug that has been selected. Some critics have argued that “innovative companies must do R&D, and this is a regular cost of doing business; so estimated profits foregone should not be added to out-of-pocket costs. If revenues are coming in from other products, then the [R&D] costs are recovered as one goes along” (Light & Warburton, 2011). Others have questioned whether the appropriate cost of capital should be as high as 11 percent, the value used in several studies from the Tufts Center for the Study of Drug Development (Tufts CSDD).

As described by Chit, et al. (2015), there is an opportunity cost associated with the use of capital, which is a scarce resource, and this cost needs to be accounted for in estimating drug development costs. The value of OCOC can vary significantly by sponsor-specific factors, such as product portfolio, venture capital funding, and size of company, as well as other exogenous factors, such as economic and regulatory climate for drug development projects. There are accepted methods in finance for estimating the opportunity cost of capital for different economic sectors and firms, including the capital asset pricing model (CAPM), and the Fama and French (F-F) 3-factor model. The CAPM model is the most widely used approach (Chit, et al., 2015).

There are several CAPM studies that evaluated OCOC for the biopharmaceutical market as a whole as well as some broad sub-sectors, such as small and large molecules. Table 8 presents the different OCOC estimates available from the published literature. For the model, we used 11 percent as the OCOC for drug development projects, which is the average of figures reported for the biopharmaceutical industry as a whole.

Table 8 Published Estimates of Opportunity Cost of Capital

Data Source | Sub-Sector | Firm Size | Study Period | Sample Size | Opportunity Cost of Capital
DiMasi et al, (2016) | All | All | 2000 | NA | 11.8%
DiMasi et al, (2016) | All | All | 2005 | NA | 10.8%
DiMasi et al, (2016) | All | All | 2010 | NA | 9.4%
DiMasi et al, (2003) | All | All | 2000 | NA | 11.9%
Damodaran, (2018) | Large Molecule | All | 2018 | 459 | 9.2%
Damodaran, (2018) | Small Molecule | All | 2018 | 185 | 8.1%
Damodaran, (2019) | Large Molecule | All | 2019 | 481 | 10.5%
Damodaran, (2019) | Small Molecule | All | 2019 | 237 | 10.5%
Paul et al, (2010) | All | All | 2007 | NA | 11.0%
Harrington, (2012) | Small Molecule | All | 2001-2005 | 31 | 9.8%
Harrington, (2012) | Small Molecule | Large | 2001-2005 | 22 | 9.6%
Harrington, (2012) | Small Molecule | Small | 2001-2005 | 9 | 10.6%
Harrington, (2012) | Large Molecule | All | 2001-2005 | 26 | 14.2%
Harrington, (2012) | Large Molecule | Large | 2001-2005 | 17 | 14.1%
Harrington, (2012) | Large Molecule | Small | 2001-2005 | 9 | 14.5%
Harrington, (2012) | Small Molecule | All | 2006-2008 | 28 | 9.3%
Harrington, (2012) | Small Molecule | Large | 2006-2008 | 21 | 9.5%
Harrington, (2012) | Small Molecule | Small | 2006-2008 | 7 | 8.6%
Harrington, (2012) | Large Molecule | All | 2006-2008 | 29 | 11.8%
Harrington, (2012) | Large Molecule | Large | 2006-2008 | 14 | 10.2%
Harrington, (2012) | Large Molecule | Small | 2006-2008 | 15 | 13.2%
Average | Large Molecule | Large | | | 12.2%
Average | Large Molecule | Small | | | 13.9%
Average | Large Molecule | All | | | 11.4%
Average | Small Molecule | Large | | | 9.6%
Average | Small Molecule | Small | | | 9.6%
Average | Small Molecule | All | | | 9.4%
Average | All | Large | | | NA
Average | All | Small | | | NA
Average | All | All ^[a]^ | | | 11.0%

NA = Not available

[a] Estimate used in this model.

## 5.8 OUT-OF-POCKET COST ESTIMATES

We calculated the total out-of-pocket cost by phase and therapeutic area as the product of per-patient cost (CPP), average number of patients enrolled per trial, and the average number of trials. The out-of-pocket cost for the FDA BLA/NDA review and approval was estimated at $2.6 million, the published FDA fee for an application requiring clinical data for fiscal year 2019 that spans October 1, 2018 through September 30, 2019 (Federal Register, 2018).

To estimate non-clinical cost, we adopted the approach by DiMasi et al (2016). There are no published data on non-clinical costs per drug candidate. Pharmaceutical companies have long claimed that it is difficult to attribute non-clinical R&D expenses to drug candidate compounds. In their 2016 study, DiMasi et al. estimated the ratio, R, of preclinical to clinical expenditures based on aggregated data on preclinical spending and assumptions around the duration of preclinical testing. Based on the reported amounts in Figure 2 of that study, they estimated the preclinical and clinical costs at $430 million and $965 million in 2013 dollars per approved drug, which translates to a ratio of 44.6 percent (DiMasi, et al., 2016). These estimates were based on data voluntarily submitted by anonymous biopharmaceutical companies as well as proprietary databases. The specifics of how they calculated this ratio is neither fully detailed in their study nor is available in other studies that are in the public domain. Thus, similar to other studies on this topic, we relied on the same reported ratio, 44.6 percent, to estimate non-clinical out of pocket costs per approved drug, which were then translated to a cost per drug candidate basis using the estimated aggregate mean success to approval rates by phase. More specifically, given that the estimated Phase 1, 2, and 3 costs are C_1_, C_2_, and C_3_) and the estimated probability of approval from a given phase, i, is P_i_, then the expected non-clinical stage cost, E(C_non−clinical_), per approved drug was calculated from equation (1) as:

E (C_n o n − c l i n i c a l_) = 0.446 × [E (C_1_) + E (C_2_) + E (C_3_)] = 0.446 × [(C_1_)/(P_1_) + (C_2_)/(P_2_) + (C_3_)/(P_3_)] Equation 11. The expected value of C sub (non-clinical) equals 0.446 times the sum of the expected values of C sub 1, C sub 2, and C sub 3. This can also be written as 0.446 times the quantity of C sub 1 over p sub 1 plus C sub 2 over p sub 2 plus C sub 3 over p sub 3. (11)

Then, using equations (1) and (11), the non-clinical cost per drug candidate was calculated as:

C_n o n − c l i n i c a l_ = E (C_n o n − c l i n i c a l_) × P_n o n − c l i n i c a l_ Equation 12. The non-clinical cost, denoted C sub (non-clinical), equals the expected non-clinical cost, E of C sub (non-clinical), multiplied by P sub (non-clinical). (12)

Given the sizable impact of non-clinical cost on overall cost of drug development, we also conducted a sensitivity analysis by varying this value +/-10 percent (Table 9). As can be observed from the table, the change in this ratio results in a proportionate change in expected capitalized cost estimate but a less than proportionate change in mean out-of-pocket cost estimate.

Table 9 Sensitivity Analysis of Varying Assumptions on Non-clinical to Clinical R&D Ratio, R, on Overall Cost Estimates

Scenario | Out-of-pocket Cost (in $ 2018 Million) ^[a]^ | Expected Cost (in $ 2018 Million) ^[b]^ | Expected Capitalized Cost (in $ 2018 Million) ^[c]^
Base Case: R = 44.6% | $172.7 | $515.8 | $879.3
Scenario 1: R = 34.6% | $170.0 | $484.6 | $800.0
Scenario 2: R = 54.6% | $175.3 | $547.1 | $958.7
Scenario 3: R ~ N(44.6%, 10%) | $172.7; ($132.8 – $199.5) | $515.8; ($322.0 – $778.0) | $879.3; ($407.0 – $1,348.0)

[a] Represents the cash outlay not adjusted for the cost of capital or failures.

[b] Represents R&D cost after adjusting for the cost of failures computed as the total out-of-pocket cost divided by the aggregate transition success probability; includes cost of failures but not the cost of capital.

[c] Represents costs inclusive of failure and capital costs.

## 5.9 RESULTS

## 5.10 BASELINE DEVELOPMENT COST ESTIMATES

According to published studies that rely on proprietary data, the cost of drug development could range from $314 million to $2.8 billion (in 2018 dollars) depending on the therapeutic area, the cost of capital or phase transition success rate assumptions used in the modeling (DiMasi, et al., 2003; Jayasundara, et al., 2019; Mestre-Ferrandiz, et al., 2012; Adams & Brantner, 2006; Adams & Brantner, 2010; DiMasi & Grabowski, 2007; DiMasi, et al., 2004; DiMasi, et al., 2016; Paul, et al., 2010). Recent studies that have used publicly available data (mainly data reported by biopharmaceutical companies to the Securities and Exchange Commission in their annual 10-K and Quarterly 10-Q filings) report cost figures that range from $734 million for cancer (Prasad & Mailankody, 2017) to $4,461.2 million for antineoplastic and immunomodulating agents (Wouters, et al., 2020) (see Table 10).

Our analysis suggests that the average out-of-pocket cost of developing a new drug is around $131.8 million before conducting post-approval studies, and approximately $172.7 million when post-approval studies are accounted for (see Table 11). Of those costs inclusive of post-approval Phase 4 studies, 7 percent is non-clinical stage related, 68 percent is clinical stage (i.e., Phase 1, 2, and 3) related, 2 percent is review phase, and the remaining 24 percent is associated with post-approval stage, which includes Phase 3 follow-up studies, where applicable, and Phase 4 post-marketing studies. When capitalized to account for cost of capital and after accounting for the costs of failures, expected capitalized average development cost for new drug development is approximately $844.6 million before conducting post-approval studies and $879.3 million after conducting them. These development costs vary widely depending on therapeutic area as shown in Table 11. At one end of the spectrum are anti-infective drugs that cost about a third of this estimate ($378.7 million including post approval study costs) and at the other end are pain and anesthesia drugs that are more than four times as costly to develop ($1,756.2 million including Phase 4 costs).

Table 10 Recent Published Estimates of Cost of Drug Development

Source | N | Cost of Capital | Type | Average Cost (in 2018 $)
Prasad & Mailankody (2017) | 10 | 7% | Cancer | $734.0 million (95% CI: $342.6 to $1,125.8 million) ^[a]^
Wouters, et al. (2020) | 20 | 10.5% | Antineoplastic & Immunomodulating Agents | $4,461.2 million (95% CI: $3,114.0 to $6,001.3 million)
Wouters, et al. (2020) | 15 | 10.5% | Alimentary Tract and Metabolism | $1,430.3 million (95% CI: $920.8 to $2,078.7 million)
Wouters, et al. (2020) | 8 | 10.5% | Nervous System | $1,076.9 million (95% CI: $508.7 to $1,847.1 million)
Wouters, et al. (2020) | 5 | 10.5% | Anti-infectives for Systemic Use | $1,297.2 million (95% CI: $672.5 to $1,858.5 million)
Wouters, et al. (2020) | 4 | 10.5% | Dermatologicals | $1,998.3 million ^[b]^
Wouters, et al. (2020) | 3 | 10.5% | Cardiovascular System | $1,152.4 million ^[b]^
Wouters, et al. (2020) | 3 | 10.5% | Musculoskeletal System | $937.3 million ^[b]^
Wouters, et al. (2020) | 2 | 10.5% | Blood and Blood-forming Organs | $793.0 million ^[b]^
Wouters, et al. (2020) | 2 | 10.5% | Sensory Organs | $1,302.8 million ^[b]^
Wouters, et al. (2020) | 1 | 10.5% | Other | $1,121.0 million ^[b]^
Wouters, et al. (2020) | 63 | 10.5% | Overall | $1,335.9 million (95% CI: $1,042.5 to-$1,637.5 million)

CI = Confidence interval

[a] The reported study estimates were in 2017 dollars. We used the Medical Care Price Index to inflate 2017 to 2018 dollars.

[b] Study authors did not calculate bootstrapped confidence intervals for those therapeutic areas with less than n = 5 samples.

Table 11 Average Cost of Developing a Drug for the U.S. Market (in Million $ 2018)

Parameter | Phase | Anti-Infective | Cardiovascular | Central Nervous System | Dermatology | Endocrine | Gastrointestinal | Genitourinary System | Hematology | Oncology | Respiratory System | Ophthalmology | Pain and Anesthesia | Immunomodulation | All Therapeutic Areas
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Non-clinical | $9.4 | $10.1 | $8.7 | $9.3 | $14.2 | $11.4 | $7.7 | $17.9 | $7.0 | $9.0 | $32.0 | $22.2 | $11.6 | $11.8
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Non-clinical | 9% | 7% | 8% | 6% | 8% | 5% | 11% | 12% | 8% | 5% | 12% | 7% | 10% | 7%
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Clinical Phases | $66.7 | $106.6 | $82.3 | $92.0 | $112.0 | $88.7 | $55.3 | $101.3 | $60.3 | $107.4 | $203.4 | $255.1 | $83.5 | $117.4
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Clinical Phases | 61% | 69% | 73% | 64% | 62% | 41% | 76% | 66% | 71% | 64% | 79% | 86% | 70% | 68%
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Phase 1 | $2.8 | $4.2 | $6.8 | $6.5 | $6.8 | $4.3 | $4.2 | $17.3 | $8.1 | $3.2 | $7.6 | $6.1 | $6.8 | $7.1
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Phase 1 | 3% | 3% | 6% | 5% | 4% | 2% | 6% | 11% | 10% | 2% | 3% | 2% | 6% | 4%
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Phase 2 | $22.3 | $11.2 | $16.1 | $14.9 | $19.4 | $26.2 | $19.8 | $22.1 | $14.5 | $13.7 | $22.8 | $34.6 | $24.3 | $21.0
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Phase 2 | 20% | 7% | 14% | 10% | 11% | 12% | 27% | 14% | 17% | 8% | 9% | 12% | 20% | 12%
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Phase 3 | $41.6 | $91.2 | $59.4 | $70.6 | $85.8 | $58.1 | $31.3 | $61.9 | $37.7 | $90.5 | $173.0 | $214.4 | $52.4 | $89.3
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Phase 3 | 38% | 59% | 53% | 49% | 47% | 27% | 43% | 40% | 45% | 54% | 68% | 72% | 44% | 52%
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | FDA Submission | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6 | $2.6
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | FDA Submission | 2% | 2% | 2% | 2% | 1% | 1% | 4% | 2% | 3% | 2% | 1% | 1% | 2% | 1%
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Post-approval Phase | $30.7 | $34.2 | $19.4 | $39.8 | $52.3 | $114.0 | $6.9 | $31.1 | $14.8 | $48.8 | $18.2 | $17.4 | $21.5 | $40.9
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Post-approval Phase | 28% | 22% | 17% | 28% | 29% | 53% | 9% | 20% | 17% | 29% | 7% | 6% | 18% | 24%
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Total (without Phase 4 costs) | $78.7 | $119.3 | $93.6 | $103.9 | $128.9 | $102.7 | $65.7 | $121.8 | $69.9 | $118.9 | $238.0 | $279.9 | $97.7 | $131.8
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Total (without Phase 4 costs) | 72% | 78% | 83% | 72% | 71% | 47% | 91% | 80% | 83% | 71% | 93% | 94% | 82% | 76%
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Total (with Phase 4 costs) | $109.4 | $153.5 | $113.0 | $143.8 | $181.2 | $216.7 | $72.5 | $152.9 | $84.7 | $167.8 | $256.2 | $297.2 | $119.3 | $172.7
Out-of-Pocket Costs (in Million $ 2018) ^[b]^ | Total (with Phase 4 costs) | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100%
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Non-clinical | $60.6 | $142.3 | $129.7 | $109.6 | $128.3 | $139.8 | $65.8 | $100.9 | $171.7 | $103.8 | $229.9 | $261.1 | $98.2 | $139.1
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Non-clinical | 24% | 27% | 28% | 26% | 26% | 24% | 27% | 26% | 29% | 25% | 29% | 29% | 27% | 27%
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Clinical Phases | $136.1 | $319.2 | $291.1 | $246.1 | $287.8 | $313.7 | $147.8 | $226.4 | $385.4 | $233.0 | $515.9 | $585.9 | $220.4 | $312.2
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Clinical Phases | 54% | 61% | 63% | 59% | 59% | 53% | 61% | 59% | 65% | 57% | 66% | 66% | 61% | 61%
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Phase 1 | $12.1 | $39.7 | $69.0 | $52.3 | $41.5 | $35.6 | $24.5 | $66.2 | $134.2 | $25.0 | $37.2 | $49.0 | $39.1 | $57.1
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Phase 1 | 5% | 8% | 15% | 12% | 8% | 6% | 10% | 17% | 23% | 6% | 5% | 6% | 11% | 11%
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Phase 2 | $64.5 | $69.6 | $100.0 | $71.8 | $80.9 | $156.1 | $72.2 | $61.9 | $148.0 | $74.2 | $95.8 | $166.5 | $97.2 | $100.9
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Phase 2 | 26% | 13% | 22% | 17% | 16% | 26% | 30% | 16% | 25% | 18% | 12% | 19% | 27% | 20%
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Phase 3 | $59.5 | $209.9 | $122.1 | $121.9 | $165.4 | $122.0 | $51.1 | $98.3 | $103.3 | $133.8 | $383.0 | $370.4 | $84.1 | $154.3
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Phase 3 | 24% | 40% | 26% | 29% | 34% | 21% | 21% | 26% | 17% | 33% | 49% | 42% | 23% | 30%
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | FDA Submission | $23.6 | $23.6 | $23.6 | $23.6 | $23.6 | $23.6 | $23.6 | $23.6 | $23.6 | $23.6 | $23.6 | $23.6 | $23.6 | $23.6
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | FDA Submission | 9% | 5% | 5% | 6% | 5% | 4% | 10% | 6% | 4% | 6% | 3% | 3% | 6% | 5%
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Post-approval Phase | $30.7 | $34.2 | $19.4 | $39.8 | $52.3 | $114.0 | $6.9 | $31.1 | $14.8 | $48.8 | $18.2 | $17.4 | $21.5 | $40.9
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Post-approval Phase | 12% | 7% | 4% | 10% | 11% | 19% | 3% | 8% | 2% | 12% | 2% | 2% | 6% | 8%
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Total (without Phase 4 costs) | $220.3 | $485.1 | $444.3 | $379.3 | $439.7 | $477.1 | $237.2 | $350.8 | $580.7 | $360.5 | $769.4 | $870.6 | $342.1 | $474.9
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Total (without Phase 4 costs) | 88% | 93% | 96% | 90% | 89% | 81% | 97% | 92% | 98% | 88% | 98% | 98% | 94% | 92%
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Total (with Phase 4 costs) | $251.0 | $519.3 | $463.7 | $419.1 | $492.0 | $591.1 | $244.0 | $381.9 | $595.5 | $409.3 | $787.6 | $887.9 | $363.7 | $515.8
Expected Out-of-Pocket Costs (in Million $ 2018) ^[c]^ | Total (with Phase 4 costs) | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100%
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Non-clinical | $21.1 | $25.9 | $24.2 | $22.8 | $32.5 | $29.5 | $16.8 | $50.5 | $20.3 | $23.1 | $68.4 | $65.0 | $27.0 | $30.1
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Non-clinical | 15% | 13% | 15% | 13% | 14% | 12% | 16% | 21% | 16% | 11% | 20% | 14% | 16% | 13%
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Clinical Phases | $89.3 | $145.2 | $122.0 | $120.0 | $152.5 | $124.9 | $77.7 | $157.6 | $88.8 | $146.2 | $251.6 | $384.9 | $117.1 | $158.7
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Clinical Phases | 64% | 72% | 74% | 67% | 66% | 49% | 75% | 66% | 72% | 68% | 74% | 82% | 71% | 70%
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Phase 1 | $4.9 | $8.6 | $15.0 | $12.2 | $12.6 | $8.4 | $7.5 | $37.9 | $17.5 | $6.5 | $13.0 | $13.7 | $12.9 | $13.8
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Phase 1 | 3% | 4% | 9% | 7% | 5% | 3% | 7% | 16% | 14% | 3% | 4% | 3% | 8% | 6%
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Phase 2 | $34.0 | $19.4 | $29.0 | $23.3 | $31.3 | $43.2 | $31.0 | $40.4 | $25.4 | $23.6 | $33.8 | $64.6 | $39.0 | $34.0
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Phase 2 | 24% | 10% | 17% | 13% | 13% | 17% | 30% | 17% | 21% | 11% | 10% | 14% | 24% | 15%
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Phase 3 | $50.5 | $117.2 | $78.1 | $84.4 | $108.6 | $73.3 | $39.2 | $79.4 | $45.8 | $116.0 | $204.9 | $306.6 | $65.2 | $110.9
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Phase 3 | 36% | 58% | 47% | 47% | 47% | 29% | 38% | 33% | 37% | 54% | 60% | 66% | 40% | 49%
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | FDA Submission | $2.8 | $2.8 | $2.9 | $2.7 | $2.8 | $2.8 | $2.8 | $2.8 | $2.7 | $2.8 | $2.7 | $3.0 | $2.8 | $2.8
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | FDA Submission | 2% | 1% | 2% | 2% | 1% | 1% | 3% | 1% | 2% | 1% | 1% | 1% | 2% | 1%
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Post-approval Phase | $25.8 | $28.9 | $16.6 | $33.9 | $45.0 | $96.9 | $6.0 | $26.7 | $12.1 | $41.5 | $15.9 | $14.8 | $18.1 | $34.7
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Post-approval Phase | 19% | 14% | 10% | 19% | 19% | 38% | 6% | 11% | 10% | 19% | 5% | 3% | 11% | 15%
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Total (without Phase 4 costs) | $113.2 | $173.9 | $149.1 | $145.5 | $187.8 | $157.2 | $97.3 | $210.9 | $111.8 | $172.2 | $322.8 | $452.8 | $146.9 | $191.5
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Total (without Phase 4 costs) | 81% | 86% | 90% | 81% | 81% | 62% | 94% | 89% | 90% | 81% | 95% | 97% | 89% | 85%
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Total (with Phase 4 costs) | $139.1 | $202.7 | $165.7 | $179.4 | $232.7 | $254.0 | $103.3 | $237.7 | $123.9 | $213.7 | $338.6 | $467.6 | $165.0 | $226.3
Capitalized Out-of-pocket Costs to Date of Launch (in Million $ 2018) ^[d]^ | Total (with Phase 4 costs) | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100%
Expected | Non-clinical | $136.1 | $363.6 | $359.8 | $268.5 | $292.5 | $360.5 | $143.0 | $284.2 | $496.6 | $268.4 | $491.8 | $764.1 | $227.6 | $353.5
Expected | Non-clinical | 36% | 41% | 40% | 39% | 38% | 37% | 36% | 39% | 41% | 39% | 41% | 44% | 38% | 40%
Expected | Clinical Phases | $191.6 | $472.1 | $492.2 | $355.8 | $416.8 | $480.5 | $220.2 | $384.1 | $676.0 | $350.8 | $659.0 | $950.0 | $334.7 | $465.7
Expected | Clinical Phases | 51% | 53% | 55% | 52% | 53% | 50% | 56% | 53% | 56% | 51% | 55% | 54% | 55% | 53%
Expected | Phase 1 | $21.3 | $82.3 | $151.5 | $97.8 | $77.1 | $70.1 | $43.4 | $144.9 | $290.8 | $51.5 | $63.4 | $109.5 | $73.7 | $110.6
Expected | Phase 1 | 6% | 9% | 17% | 14% | 10% | 7% | 11% | 20% | 24% | 8% | 5% | 6% | 12% | 13%
Expected | Phase 2 | $98.0 | $120.2 | $180.2 | $112.1 | $130.4 | $256.7 | $112.7 | $113.2 | $259.7 | $127.6 | $142.2 | $310.7 | $156.3 | $163.4
Expected | Phase 2 | 26% | 14% | 20% | 16% | 17% | 27% | 29% | 16% | 21% | 19% | 12% | 18% | 26% | 19%
Expected | Phase 3 | $72.2 | $269.7 | $160.5 | $145.9 | $209.3 | $153.8 | $64.0 | $126.0 | $125.4 | $171.6 | $453.4 | $529.8 | $104.6 | $191.6
Expected | Phase 3 | 19% | 30% | 18% | 21% | 27% | 16% | 16% | 17% | 10% | 25% | 38% | 30% | 17% | 22%
Expected | FDA Submission | $25.2 | $25.8 | $26.0 | $24.9 | $25.7 | $25.6 | $25.7 | $25.3 | $24.6 | $25.7 | $24.9 | $27.3 | $25.5 | $25.4
Expected | FDA Submission | 7% | 3% | 3% | 4% | 3% | 3% | 6% | 4% | 2% | 4% | 2% | 2% | 4% | 3%
Expected | Post-approval Phase | $25.8 | $28.9 | $16.6 | $33.9 | $45.0 | $96.9 | $6.0 | $26.7 | $12.1 | $41.5 | $15.9 | $14.8 | $18.1 | $34.7
Expected | Post-approval Phase | 7% | 3% | 2% | 5% | 6% | 10% | 2% | 4% | 1% | 6% | 1% | 1% | 3% | 4%
Expected | Total (without Phase 4 costs) | $352.9 | $861.5 | $878.0 | $649.3 | $735.0 | $866.6 | $388.9 | $693.6 | $1,197.2 | $644.9 | $1,175.8 | $1,741.5 | $587.7 | $844.6
Expected | Total (without Phase 4 costs) | 93% | 97% | 98% | 95% | 94% | 90% | 98% | 96% | 99% | 94% | 99% | 99% | 97% | 96%
Expected | Total (with Phase 4 costs) | $378.7 | $890.3 | $894.6 | $683.1 | $780.0 | $963.5 | $394.9 | $720.4 | $1,209.2 | $686.4 | $1,191.6 | $1,756.2 | $605.8 | $879.3
Expected | Total (with Phase 4 costs) | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100% | 100%

NA = Not applicable

Figures may not add up due to rounding.

[a] The figure represents the transition probability from the given stage to approval.

[b] These are the raw out-of-pocket expenses not adjusted for opportunity cost of capital or failures.

[c] The figures represent the out-of-pocket expenses after adjusting for the cost of failures computed as the raw out-of-pocket cost divided by the transition success probability. Expected out-of-pocket costs take into account the costs of failures but not the cost of capital.

[d] The figures represent the out-of-pocket costs at the point of launch after adjusting for the cost of capital; computed in accordance with approach described in Section 3. Capitalized out-of-pocket costs take into account the cost of capital but not the costs of failures.

[e] Expected capitalized costs take into account the costs of failures and the cost of capital.

As indicated, expected capitalized costs are higher than out-of-pocket costs because they consider the opportunity cost of capital that embodies the time value of money and the fact that there will be failures along the way. The figures presented in Table 11 represent our baseline cost of new drug development against which we evaluate different strategies designed to improve likelihood of phase transition success and/or reduce non-clinical, clinical, FDA NDA/BLA phase, and post-approval related costs and durations.

As Table 11 illustrates, the primary driver of development cost is clinical stage followed by non-clinical stage expenditures when we account for cost of failures and cost of capital. From a capitalized out-of-pocket cost perspective that takes account of the time value of the investment but not failure costs, non-clinical and clinical development stages account for 13 percent and 70 percent of total capitalized development costs, respectively, whether or not post-approval Phase 4 study costs are included.

From an expected capitalized cost perspective in which both cost of failures and the time value of the investment are incorporated, the share of total expected development cost represented by the non-clinical stage is 40 percent, inclusive of post-approval study costs. Non-clinical stage represents the second largest portion of total expected capitalized development costs following the clinical stage at 53 percent primarily because the probability of moving from non-clinical stage to a marketable drug is only 8.5 percent on average. Thus, the $11.8 million and nearly 3 years needed to conduct non-clinical studies are much greater in real economic impact than their nominal value suggests. As the drug developer successfully transitions from one development stage to another, the likelihood of approval hence expected returns change. Even though a large, Phase 3 study may be more expensive out-of-pocket than non-clinical work, the odds of a drug candidate making it to market is significantly higher (65.5 percent) if the new drug candidate has already cleared the non-clinical, Phase 1, and Phase 2 stages than one that is at the target identification stage (8.5 percent).

The clinical phases of drug development (Phase 1, 2, and 3) are the largest contributor to total out of pocket development costs, comprising around 68 percent of total costs inclusive of post-approval studies. From a capitalized out-of-pocket cost perspective, clinical development comprises 70 percent of total capitalized development costs, including post-approval costs but excluding the time value of the investment. From an expected capitalized out-of-pocket cost perspective, the share of total expected capitalized development costs represented by clinical development is around 53 percent, including post-approval study costs. Phase 3 costs constitute the vast majority of clinical development costs, due primarily to enrolling large number of patients (approximately 630 versus 51 for Phase 1), taking longer than Phase 1 (38.0 months versus 27.8 months), and greater out-of-pocket costs (approximately $89.3 million vs. $7.1 million).

It is important to note that the estimated costs presented in this study do not include some significant elements, such as development of chemistry, manufacturing, and controls (CMC), and manufacturing plant design and build, which could be significant.

## 5.11 IMPACT OF SELECT CLINICAL TRIAL STRATEGIES ON THE TOTAL COST OF DRUG DEVELOPMENT

As described in our previous study (Eastern Research Group, Inc., 2022), we asked our panel of experts to evaluate the impact of various clinical study strategies on the cost, duration, and phase transition success probability of drug development stages. A summary of our experts’ estimates is presented in Table 12 and estimates by therapeutic area are provided in Appendix A. Negative percentages indicate reductions in a given parameter (e.g., use of mobile technologies would reduce clinical study costs, on average, by 3 percent during Phase 1 holding all other factors constant), and positive percentages indicate increases in a given parameter (e.g., using biomarkers as surrogate endpoints would increase a developer’s probability of successfully transitioning from Phase 2 to Phase 3, on average, by 2 percent across all therapeutic areas holding all other factors constant).

We then evaluated the overall impact of each strategy on total expected development cost (see Table 13). Using our total expected capitalized cost (including post-approval studies) estimates as our baseline, we evaluated the change (or delta [Δ]) to this total expected cost if a developer were to implement a given strategy across all therapeutic areas. For each strategy, we evaluated the reduction in overall expected development cost attributable to the cost savings, time savings, and increases in phase transition success probability associated with that strategy. For example, use of adaptive design in clinical trial protocols are associated with sponsor overall cost savings of 22.8 percent, time savings of 1.6 percent, and a phase transition success probability increase of 19.2 percent (Table 13). When incorporated into our drug development cost model, these changes result in a total expected capitalized development cost of $678.7 million, which is 22.8 percent lower than our baseline estimate of $879.3 million.

From Table 13, the strategy with the largest impact on overall development costs across all therapeutic areas is Improvements in FDA Review Process Efficiency and Interactions (−27.1 percent), followed by Adaptive Design (−22.8 percent), and implementation of a Simplified Clinical Trial Protocols and Reduced Amendments (−22.2 percent). Those strategies with the lowest expected development cost savings across all therapeutic areas include Use of Patient Registries (−9.9 percent), Biomarkers as Surrogate Endpoints (−13.3 percent), and Electronic Health Records (−13.6 percent).

Table 12 Expert Estimates of Strategy Impacts on Cost, Duration, and Probability of Phase Transition Success for Drugs (All Therapeutic Areas Combined)

Strategy | Phase | Cost | Duration | Success Likelihood
Mobile Technologies | Non-clinical | −1% | 0% | 0%
Mobile Technologies | Phase 1 | −3% | −3% | 2%
Mobile Technologies | Phase 2 | −8% | −6% | 4%
Mobile Technologies | Phase 3 | −15% | −9% | 5%
Mobile Technologies | FDA Review | −6% | −1% | 1%
Mobile Technologies | Phase 4 | −21% | −9% | NA
Simplified Clinical Trial Protocols and Reduced Amendments | Non-clinical | −4% | −3% | 0%
Simplified Clinical Trial Protocols and Reduced Amendments | Phase 1 | −5% | −5% | 1%
Simplified Clinical Trial Protocols and Reduced Amendments | Phase 2 | −9% | −8% | 4%
Simplified Clinical Trial Protocols and Reduced Amendments | Phase 3 | −13% | −9% | 6%
Simplified Clinical Trial Protocols and Reduced Amendments | FDA Review | −3% | −3% | 1%
Simplified Clinical Trial Protocols and Reduced Amendments | Phase 4 | −10% | −7% | NA
Reduced SDV | Non-clinical | −1% | 0% | 0%
Reduced SDV | Phase 1 | −5% | −2% | 0%
Reduced SDV | Phase 2 | −10% | −5% | 0%
Reduced SDV | Phase 3 | −18% | −10% | 0%
Reduced SDV | FDA Review | −12% | −7% | 0%
Reduced SDV | Phase 4 | −17% | −7% | NA
Improvements in FDA Review Efficiency and Interactions | Non-clinical | −1% | 0% | 4%
Improvements in FDA Review Efficiency and Interactions | Phase 1 | −2% | −2% | 2%
Improvements in FDA Review Efficiency and Interactions | Phase 2 | −4% | −3% | 10%
Improvements in FDA Review Efficiency and Interactions | Phase 3 | −10% | −8% | 13%
Improvements in FDA Review Efficiency and Interactions | FDA Review | −2% | −1% | 6%
Improvements in FDA Review Efficiency and Interactions | Phase 4 | −5% | −3% | NA
Staged Approval | Non-clinical | 0% | 0% | 0%
Staged Approval | Phase 1 | 0% | 0% | 2%
Staged Approval | Phase 2 | −2% | −2% | 7%
Staged Approval | Phase 3 | −12% | −9% | 6%
Staged Approval | FDA Review | −5% | −5% | 4%
Staged Approval | Phase 4 | −1% | −1% | NA
Biomarkers as Surrogate Endpoints | Non-clinical | −4% | −2% | 5%
Biomarkers as Surrogate Endpoints | Phase 1 | −3% | −2% | 6%
Biomarkers as Surrogate Endpoints | Phase 2 | −1% | −3% | 2%
Biomarkers as Surrogate Endpoints | Phase 3 | −5% | −3% | 4%
Biomarkers as Surrogate Endpoints | FDA Review | −3% | −3% | 2%
Biomarkers as Surrogate Endpoints | Phase 4 | −3% | −2% | NA
Electronic Health Records | Non-clinical | −1% | −1% | 0%
Electronic Health Records | Phase 1 | 0% | −3% | 2%
Electronic Health Records | Phase 2 | −5% | −4% | 2%
Electronic Health Records | Phase 3 | −8% | −8% | 3%
Electronic Health Records | Phase 3L | −9% | −9% | 3%
Electronic Health Records | Phase 3N | −8% | −8% | 3%
Electronic Health Records | FDA Review | −5% | −7% | 1%
Electronic Health Records | Phase 4 | −15% | −13% | NA
Patient Registries | Non-clinical | 0% | 0% | 0%
Patient Registries | Phase 1 | −5% | −5% | 0%
Patient Registries | Phase 2 | −5% | −5% | 0%
Patient Registries | Phase 3 | −6% | −6% | 1%
Patient Registries | Phase 3L | −8% | −8% | 2%
Patient Registries | Phase 3N | −6% | −6% | 1%
Patient Registries | FDA Review | −4% | −5% | 0%
Patient Registries | Phase 4 | −7% | −8% | NA
Adaptive Design | Non-clinical | 0% | 0% | 0%
Adaptive Design | Phase 1 | 6% | 7% | 4%
Adaptive Design | Phase 2 | −1% | 1% | 14%
Adaptive Design | Phase 3 | −8% | −9% | 10%
Adaptive Design | FDA Review | −1% | −2% | 6%
Adaptive Design | Phase 4 | −3% | −3% | NA
Standardized Contracts | Non-clinical | −4% | −5% | 0%
Standardized Contracts | Phase 1 | −6% | −7% | 0%
Standardized Contracts | Phase 2 | −7% | −9% | 0%
Standardized Contracts | Phase 3 | −9% | −12% | 0%
Standardized Contracts | FDA Review | −3% | −5% | 0%
Standardized Contracts | Phase 4 | −8% | −9% | NA

NA = Not applicable

The zero percentages represent those cases where an expert indicated that the strategy was not relevant to a particular phase and/or cost, duration, or probability of phase transition success associated with that phase.[

Table 13 Impacts of Clinical Trial Strategies on Baseline Cost, Duration, and Phase Transition Success Probability – Drugs

Strategy | Therapeutic Area (TA) | Change from Baseline due to…
Strategy | Therapeutic Area (TA) | Change in Cost | | Change in Duration | | Change in Success Probability | | Total Change ^[a]^
Strategy | Therapeutic Area (TA) | $ | % | $ | % | $ | % | $ | %
Mobile Technologies | Anti-Infective | −$35.9 | −9.5% | −$10.6 | −2.8% | −$22.4 | −5.9% | −$63.8 | −16.9%
Mobile Technologies | Cardiovascular | −$103.3 | −11.6% | −$37.6 | −4.2% | −$70.9 | −8.0% | −$193.6 | −21.7%
Mobile Technologies | Central Nervous System | −$85.1 | −9.5% | −$45.4 | −5.1% | −$70.9 | −7.9% | −$183.3 | −20.5%
Mobile Technologies | Dermatology | −$71.6 | −10.5% | −$27.8 | −4.1% | −$49.8 | −7.3% | −$136.5 | −20.0%
Mobile Technologies | Endocrine | −$92.0 | −11.8% | −$29.9 | −3.8% | −$71.0 | −9.1% | −$176.2 | −22.6%
Mobile Technologies | Gastrointestinal | −$107.2 | −11.1% | −$37.4 | −3.9% | −$68.7 | −7.1% | −$195.8 | −20.3%
Mobile Technologies | Genitourinary System | −$37.6 | −9.5% | −$13.8 | −3.5% | −$30.4 | −7.7% | −$74.9 | −19.0%
Mobile Technologies | Hematology | −$67.5 | −9.4% | −$40.2 | −5.6% | −$56.0 | −7.8% | −$149.1 | −20.7%
Mobile Technologies | Oncology | −$83.0 | −6.9% | −$69.0 | −5.7% | −$105.3 | −8.7% | −$235.3 | −19.5%
Mobile Technologies | Respiratory System | −$83.5 | −12.2% | −$30.0 | −4.4% | −$40.1 | −5.8% | −$141.2 | −20.6%
Mobile Technologies | Ophthalmology | −$151.2 | −12.7% | −$39.7 | −3.3% | −$77.5 | −6.5% | −$245.6 | −20.6%
Mobile Technologies | Pain and Anesthesia | −$216.3 | −12.3% | −$73.8 | −4.2% | −$114.8 | −6.5% | −$369.5 | −21.0%
Mobile Technologies | Immunomodulation | −$55.1 | −9.1% | −$22.3 | −3.7% | −$43.2 | −7.1% | −$110.9 | −18.3%
Mobile Technologies | All Therapeutic Areas | −$93.1 | −10.6% | −$36.7 | −4.2% | −$64.9 | −7.4% | −$178.0 | −20.2%
Simplified Clinical Trial Protocols and Reduced Amendments | Anti-Infective | −$38.0 | −10.0% | −$16.2 | −4.3% | −$28.6 | −7.6% | −$70.4 | −18.6%
Simplified Clinical Trial Protocols and Reduced Amendments | Cardiovascular | −$130.1 | −14.6% | −$58.3 | −6.5% | −$112.1 | −12.6% | −$254.8 | −28.6%
Simplified Clinical Trial Protocols and Reduced Amendments | Central Nervous System | −$94.6 | −10.6% | −$63.0 | −7.0% | −$88.2 | −9.9% | −$205.1 | −22.9%
Simplified Clinical Trial Protocols and Reduced Amendments | Dermatology | −$74.4 | −10.9% | −$40.4 | −5.9% | −$63.0 | −9.2% | −$148.6 | −21.8%
Simplified Clinical Trial Protocols and Reduced Amendments | Endocrine | −$98.8 | −12.7% | −$42.7 | −5.5% | −$63.8 | −8.2% | −$174.1 | −22.3%
Simplified Clinical Trial Protocols and Reduced Amendments | Gastrointestinal | −$106.3 | −11.0% | −$55.0 | −5.7% | −$86.8 | −9.0% | −$208.1 | −21.6%
Simplified Clinical Trial Protocols and Reduced Amendments | Genitourinary System | −$41.1 | −10.4% | −$20.2 | −5.1% | −$37.7 | −9.5% | −$83.2 | −21.1%
Simplified Clinical Trial Protocols and Reduced Amendments | Hematology | −$74.2 | −10.3% | −$54.5 | −7.6% | −$69.4 | −9.6% | −$165.4 | −23.0%
Simplified Clinical Trial Protocols and Reduced Amendments | Oncology | −$109.4 | −9.0% | −$102.0 | −8.4% | −$121.4 | −10.0% | −$282.3 | −23.3%
Simplified Clinical Trial Protocols and Reduced Amendments | Respiratory System | −$82.4 | −12.0% | −$36.5 | −5.3% | −$52.3 | −7.6% | −$145.2 | −21.2%
Simplified Clinical Trial Protocols and Reduced Amendments | Ophthalmology | −$150.7 | −12.7% | −$60.0 | −5.0% | −$104.5 | −8.8% | −$263.3 | −22.1%
Simplified Clinical Trial Protocols and Reduced Amendments | Pain and Anesthesia | −$238.7 | −13.6% | −$110.4 | −6.3% | −$151.9 | −8.7% | −$420.0 | −23.9%
Simplified Clinical Trial Protocols and Reduced Amendments | Immunomodulation | −$63.1 | −10.4% | −$32.4 | −5.3% | −$53.9 | −8.9% | −$126.2 | −20.8%
Simplified Clinical Trial Protocols and Reduced Amendments | All Therapeutic Areas | −$97.7 | −11.1% | −$53.7 | −6.1% | −$82.5 | −9.4% | −$195.1 | −22.2%
Reduced SDV | Anti-Infective | −$42.1 | −11.1% | −$12.9 | −3.4% | −$2.9 | −0.8% | −$54.6 | −14.4%
Reduced SDV | Cardiovascular | −$141.0 | −15.8% | −$67.0 | −7.5% | $57.9 | 6.5% | −$127.5 | −14.3%
Reduced SDV | Central Nervous System | −$105.2 | −11.8% | −$54.0 | −6.0% | −$9.7 | −1.1% | −$156.4 | −17.5%
Reduced SDV | Dermatology | −$86.5 | −12.7% | −$33.5 | −4.9% | −$6.9 | −1.0% | −$118.0 | −17.3%
Reduced SDV | Endocrine | −$98.4 | −12.6% | −$31.7 | −4.1% | −$6.7 | −0.9% | −$128.3 | −16.4%
Reduced SDV | Gastrointestinal | −$121.8 | −12.6% | −$45.2 | −4.7% | −$9.2 | −1.0% | −$164.5 | −17.1%
Reduced SDV | Genitourinary System | −$46.2 | −11.7% | −$17.3 | −4.4% | −$4.0 | −1.0% | −$63.0 | −16.0%
Reduced SDV | Hematology | −$83.9 | −11.6% | −$48.7 | −6.8% | −$7.8 | −1.1% | −$129.8 | −18.0%
Reduced SDV | Oncology | −$102.2 | −8.4% | −$75.1 | −6.2% | −$11.7 | −1.0% | −$175.5 | −14.5%
Reduced SDV | Respiratory System | −$85.1 | −12.4% | −$31.9 | −4.6% | −$5.4 | −0.8% | −$114.7 | −16.7%
Reduced SDV | Ophthalmology | −$183.0 | −15.4% | −$46.8 | −3.9% | −$10.6 | −0.9% | −$225.0 | −18.9%
Reduced SDV | Pain and Anesthesia | −$232.5 | −13.2% | −$95.5 | −5.4% | −$15.7 | −0.9% | −$319.2 | −18.2%
Reduced SDV | Immunomodulation | −$66.7 | −11.0% | −$26.8 | −4.4% | −$5.7 | −0.9% | −$92.7 | −15.3%
Reduced SDV | All Therapeutic Areas | −$112.3 | −12.8% | −$43.3 | −4.9% | −$8.9 | −1.0% | −$153.1 | −17.4%
Improvements in FDA Review Efficiency and Interactions | Anti-Infective | −$22.4 | −5.9% | −$10.3 | −2.7% | −$66.3 | −17.5% | −$91.1 | −24.1%
Improvements in FDA Review Efficiency and Interactions | Cardiovascular | −$80.8 | −9.1% | −$37.3 | −4.2% | −$170.5 | −19.1% | −$260.3 | −29.2%
Improvements in FDA Review Efficiency and Interactions | Central Nervous System | −$50.3 | −5.6% | −$35.7 | −4.0% | −$190.2 | −21.3% | −$252.5 | −28.2%
Improvements in FDA Review Efficiency and Interactions | Dermatology | −$41.4 | −6.1% | −$22.1 | −3.2% | −$135.1 | −19.8% | −$181.9 | −26.6%
Improvements in FDA Review Efficiency and Interactions | Endocrine | −$66.2 | −8.5% | −$26.6 | −3.4% | −$138.2 | −17.7% | −$209.9 | −26.9%
Improvements in FDA Review Efficiency and Interactions | Gastrointestinal | −$55.3 | −5.7% | −$30.4 | −3.2% | −$186.9 | −19.4% | −$250.0 | −25.9%
Improvements in FDA Review Efficiency and Interactions | Genitourinary System | −$21.0 | −5.3% | −$11.2 | −2.8% | −$82.0 | −20.8% | −$105.3 | −26.7%
Improvements in FDA Review Efficiency and Interactions | Hematology | −$40.1 | −5.6% | −$33.0 | −4.6% | −$149.4 | −20.7% | −$202.6 | −28.1%
Improvements in FDA Review Efficiency and Interactions | Oncology | −$50.6 | −4.2% | −$64.2 | −5.3% | −$243.4 | −20.1% | −$328.7 | −27.2%
Improvements in FDA Review Efficiency and Interactions | Respiratory System | −$42.8 | −6.2% | −$22.8 | −3.3% | −$125.0 | −18.2% | −$174.6 | −25.4%
Improvements in FDA Review Efficiency and Interactions | Ophthalmology | −$94.3 | −7.9% | −$32.4 | −2.7% | −$222.4 | −18.7% | −$318.0 | −26.7%
Improvements in FDA Review Efficiency and Interactions | Pain and Anesthesia | −$117.8 | −6.7% | −$57.6 | −3.3% | −$325.1 | −18.5% | −$457.5 | −26.0%
Improvements in FDA Review Efficiency and Interactions | Immunomodulation | −$31.4 | −5.2% | −$18.2 | −3.0% | −$118.4 | −19.5% | −$155.1 | −25.6%
Improvements in FDA Review Efficiency and Interactions | All Therapeutic Areas | −$54.2 | −6.2% | −$29.3 | −3.3% | −$176.9 | −20.1% | −$238.2 | −27.1%
Staged Approval | Anti-Infective | −$17.3 | −4.6% | −$8.8 | −2.3% | −$40.0 | −10.6% | −$63.2 | −16.7%
Staged Approval | Cardiovascular | −$53.1 | −6.0% | −$25.9 | −2.9% | −$80.7 | −9.1% | −$151.7 | −17.0%
Staged Approval | Central Nervous System | −$44.2 | −4.9% | −$37.2 | −4.2% | −$114.8 | −12.8% | −$185.4 | −20.7%
Staged Approval | Dermatology | −$38.5 | −5.6% | −$22.1 | −3.2% | −$80.8 | −11.8% | −$133.8 | −19.6%
Staged Approval | Endocrine | −$47.0 | −6.0% | −$22.0 | −2.8% | −$81.3 | −10.4% | −$142.5 | −18.3%
Staged Approval | Gastrointestinal | −$45.0 | −4.7% | −$30.9 | −3.2% | −$112.5 | −11.7% | −$178.5 | −18.5%
Staged Approval | Genitourinary System | −$18.2 | −4.6% | −$12.0 | −3.0% | −$49.6 | −12.6% | −$76.0 | −19.2%
Staged Approval | Hematology | −$35.3 | −4.9% | −$35.1 | −4.9% | −$90.3 | −12.5% | −$151.2 | −21.0%
Staged Approval | Oncology | −$37.9 | −3.1% | −$68.5 | −5.7% | −$182.3 | −15.1% | −$271.9 | −22.5%
Staged Approval | Respiratory System | −$43.8 | −6.4% | −$25.5 | −3.7% | −$81.1 | −11.8% | −$140.9 | −20.5%
Staged Approval | Ophthalmology | −$104.3 | −8.8% | −$31.5 | −2.6% | −$128.2 | −10.8% | −$248.2 | −20.8%
Staged Approval | Pain and Anesthesia | −$122.6 | −7.0% | −$64.5 | −3.7% | −$189.3 | −10.8% | −$354.3 | −20.2%
Staged Approval | Immunomodulation | −$26.7 | −4.4% | −$18.4 | −3.0% | −$70.7 | −11.7% | −$110.4 | −18.2%
Staged Approval | All Therapeutic Areas | −$50.6 | −5.7% | −$29.0 | −3.3% | −$105.7 | −12.0% | −$175.1 | −19.9%
Biomarkers as Surrogate Endpoints | Anti-Infective | −$27.5 | −7.3% | −$16.4 | −4.3% | −$30.4 | −8.0% | −$58.9 | −15.6%
Biomarkers as Surrogate Endpoints | Cardiovascular | −$38.6 | −4.3% | −$26.5 | −3.0% | −$58.5 | −6.6% | −$96.7 | −10.9%
Biomarkers as Surrogate Endpoints | Central Nervous System | −$42.8 | −4.8% | −$36.1 | −4.0% | −$81.8 | −9.1% | −$126.4 | −14.1%
Biomarkers as Surrogate Endpoints | Dermatology | −$33.8 | −4.9% | −$24.7 | −3.6% | −$58.4 | −8.6% | −$91.5 | −13.4%
Biomarkers as Surrogate Endpoints | Endocrine | −$36.0 | −4.6% | −$23.4 | −3.0% | −$57.6 | −7.4% | −$91.9 | −11.8%
Biomarkers as Surrogate Endpoints | Gastrointestinal | −$41.5 | −4.3% | −$32.9 | −3.4% | −$75.0 | −7.8% | −$115.9 | −12.0%
Biomarkers as Surrogate Endpoints | Genitourinary System | −$16.8 | −4.2% | −$12.6 | −3.2% | −$33.1 | −8.4% | −$49.1 | −12.4%
Biomarkers as Surrogate Endpoints | Hematology | −$35.3 | −4.9% | −$31.2 | −4.3% | −$66.3 | −9.2% | −$105.1 | −14.6%
Biomarkers as Surrogate Endpoints | Oncology | −$42.2 | −3.5% | −$51.5 | −4.3% | −$124.4 | −10.3% | −$181.7 | −15.0%
Biomarkers as Surrogate Endpoints | Respiratory System | −$29.3 | −4.3% | −$21.2 | −3.1% | −$46.3 | −6.7% | −$75.5 | −11.0%
Biomarkers as Surrogate Endpoints | Ophthalmology | −$67.8 | −5.7% | −$38.5 | −3.2% | −$93.5 | −7.9% | −$154.2 | −12.9%
Biomarkers as Surrogate Endpoints | Pain and Anesthesia | −$87.5 | −5.0% | −$66.6 | −3.8% | −$134.5 | −7.7% | −$222.9 | −12.7%
Biomarkers as Surrogate Endpoints | Immunomodulation | −$30.0 | −5.0% | −$23.5 | −3.9% | −$52.8 | −8.7% | −$81.0 | −13.4%
Biomarkers as Surrogate Endpoints | All Therapeutic Areas | −$43.3 | −4.9% | −$31.9 | −3.6% | −$75.3 | −8.6% | −$117.3 | −13.3%
Electronic Health Records | Anti-Infective | −$26.0 | −6.9% | −$12.3 | −3.2% | −$13.2 | −3.5% | −$47.8 | −12.6%
Electronic Health Records | Cardiovascular | −$62.8 | −7.1% | −$40.1 | −4.5% | −$30.0 | −3.4% | −$123.0 | −13.8%
Electronic Health Records | Central Nervous System | −$46.3 | −5.2% | −$47.6 | −5.3% | −$42.8 | −4.8% | −$125.3 | −14.0%
Electronic Health Records | Dermatology | −$40.2 | −5.9% | −$30.7 | −4.5% | −$30.3 | −4.4% | −$92.8 | −13.6%
Electronic Health Records | Endocrine | −$63.2 | −8.1% | −$34.0 | −4.4% | −$30.1 | −3.9% | −$117.7 | −15.1%
Electronic Health Records | Gastrointestinal | −$62.6 | −6.5% | −$39.6 | −4.1% | −$40.6 | −4.2% | −$131.7 | −13.7%
Electronic Health Records | Genitourinary System | −$21.0 | −5.3% | −$15.4 | −3.9% | −$17.9 | −4.5% | −$49.9 | −12.7%
Electronic Health Records | Hematology | −$36.6 | −5.1% | −$43.3 | −6.0% | −$34.1 | −4.7% | −$104.6 | −14.5%
Electronic Health Records | Oncology | −$39.0 | −3.2% | −$77.0 | −6.4% | −$51.4 | −4.2% | −$154.6 | −12.8%
Electronic Health Records | Respiratory System | −$40.1 | −5.8% | −$28.0 | −4.1% | −$24.2 | −3.5% | −$85.3 | −12.4%
Electronic Health Records | Ophthalmology | −$86.2 | −7.2% | −$41.9 | −3.5% | −$48.1 | −4.0% | −$161.4 | −13.5%
Electronic Health Records | Pain and Anesthesia | −$108.9 | −6.2% | −$87.4 | −5.0% | −$69.9 | −4.0% | −$243.6 | −13.9%
Electronic Health Records | Immunomodulation | −$30.8 | −5.1% | −$23.4 | −3.9% | −$25.7 | −4.2% | −$73.6 | −12.2%
Electronic Health Records | All Therapeutic Areas | −$52.3 | −5.9% | −$38.5 | −4.4% | −$39.3 | −4.5% | −$119.4 | −13.6%
Patient Registries | Anti-Infective | −$17.9 | −4.7% | −$9.2 | −2.4% | −$3.0 | −0.8% | −$29.5 | −7.8%
Patient Registries | Cardiovascular | −$41.6 | −4.7% | −$26.3 | −3.0% | −$6.6 | −0.7% | −$72.8 | −8.2%
Patient Registries | Central Nervous System | −$48.9 | −5.5% | −$39.5 | −4.4% | −$9.3 | −1.0% | −$94.6 | −10.6%
Patient Registries | Dermatology | −$38.0 | −5.6% | −$25.6 | −3.7% | −$6.6 | −1.0% | −$68.2 | −10.0%
Patient Registries | Endocrine | −$42.7 | −5.5% | −$21.8 | −2.8% | −$6.7 | −0.9% | −$69.6 | −8.9%
Patient Registries | Gastrointestinal | −$53.8 | −5.6% | −$33.3 | −3.5% | −$9.2 | −1.0% | −$93.7 | −9.7%
Patient Registries | Genitourinary System | −$21.2 | −5.4% | −$12.0 | −3.0% | −$4.0 | −1.0% | −$36.3 | −9.2%
Patient Registries | Hematology | −$39.5 | −5.5% | −$35.7 | −5.0% | −$7.2 | −1.0% | −$79.8 | −11.1%
Patient Registries | Oncology | −$51.6 | −4.3% | −$54.3 | −4.5% | −$10.8 | −0.9% | −$113.5 | −9.4%
Patient Registries | Respiratory System | −$34.3 | −5.0% | −$24.4 | −3.6% | −$5.4 | −0.8% | −$62.4 | −9.1%
Patient Registries | Ophthalmology | −$68.4 | −5.7% | −$33.3 | −2.8% | −$10.9 | −0.9% | −$109.8 | −9.2%
Patient Registries | Pain and Anesthesia | −$91.6 | −5.2% | −$69.9 | −4.0% | −$15.8 | −0.9% | −$172.2 | −9.8%
Patient Registries | Immunomodulation | −$30.4 | −5.0% | −$18.9 | −3.1% | −$5.7 | −0.9% | −$53.7 | −8.9%
Patient Registries | All Therapeutic Areas | −$48.9 | −5.6% | −$32.5 | −3.7% | −$8.6 | −1.0% | −$87.4 | −9.9%
Adaptive Design | Anti-Infective | −$12.3 | −3.2% | −$5.8 | −1.5% | −$61.0 | −16.1% | −$76.3 | −20.1%
Adaptive Design | Cardiovascular | −$34.0 | −3.8% | −$15.9 | −1.8% | −$129.1 | −14.5% | −$172.6 | −19.4%
Adaptive Design | Central Nervous System | −$14.9 | −1.7% | −$21.6 | −2.4% | −$184.9 | −20.7% | −$215.8 | −24.1%
Adaptive Design | Dermatology | −$16.4 | −2.4% | −$9.8 | −1.4% | −$129.5 | −19.0% | −$152.3 | −22.3%
Adaptive Design | Endocrine | −$29.9 | −3.8% | −$13.3 | −1.7% | −$129.9 | −16.6% | −$166.9 | −21.4%
Adaptive Design | Gastrointestinal | −$24.7 | −2.6% | −$15.1 | −1.6% | −$180.2 | −18.7% | −$213.6 | −22.2%
Adaptive Design | Genitourinary System | −$7.5 | −1.9% | −$7.4 | −1.9% | −$79.9 | −20.2% | −$92.4 | −23.4%
Adaptive Design | Hematology | −$9.8 | −1.4% | −$21.3 | −3.0% | −$145.8 | −20.2% | −$172.2 | −23.9%
Adaptive Design | Oncology | −$17.2 | −1.4% | −$48.1 | −4.0% | −$258.5 | −21.4% | −$311.4 | −25.8%
Adaptive Design | Respiratory System | −$24.5 | −3.6% | −$13.9 | −2.0% | −$108.6 | −15.8% | −$141.2 | −20.6%
Adaptive Design | Ophthalmology | −$62.3 | −5.2% | −$17.8 | −1.5% | −$200.7 | −16.8% | −$268.7 | −22.5%
Adaptive Design | Pain and Anesthesia | −$70.7 | −4.0% | −$30.9 | −1.8% | −$300.4 | −17.1% | −$386.8 | −22.0%
Adaptive Design | Immunomodulation | −$15.4 | −2.5% | −$13.7 | −2.3% | −$116.5 | −19.2% | −$140.8 | −23.2%
Adaptive Design | All Therapeutic Areas | −$23.1 | −2.6% | −$13.7 | −1.6% | −$169.1 | −19.2% | −$200.6 | −22.8%
Standardized Contracts | Anti-Infective | −$28.4 | −7.5% | −$20.7 | −5.5% | −$6.7 | −1.8% | −$44.9 | −11.8%
Standardized Contracts | Cardiovascular | −$97.6 | −11.0% | −$76.3 | −8.6% | −$50.0 | −5.6% | −$175.4 | −19.7%
Standardized Contracts | Central Nervous System | −$77.6 | −8.7% | −$77.6 | −8.7% | −$20.7 | −2.3% | −$140.6 | −15.7%
Standardized Contracts | Dermatology | −$59.9 | −8.8% | −$49.7 | −7.3% | −$15.1 | −2.2% | −$99.1 | −14.5%
Standardized Contracts | Endocrine | −$71.9 | −9.2% | −$50.4 | −6.5% | −$15.2 | −1.9% | −$111.4 | −14.3%
Standardized Contracts | Gastrointestinal | −$83.8 | −8.7% | −$68.1 | −7.1% | −$20.7 | −2.1% | −$138.0 | −14.3%
Standardized Contracts | Genitourinary System | −$33.1 | −8.4% | −$25.3 | −6.4% | −$8.5 | −2.1% | −$53.2 | −13.5%
Standardized Contracts | Hematology | −$61.8 | −8.6% | −$67.0 | −9.3% | −$16.3 | −2.3% | −$116.9 | −16.2%
Standardized Contracts | Oncology | −$83.6 | −6.9% | −$113.6 | −9.4% | −$23.4 | −1.9% | −$181.1 | −15.0%
Standardized Contracts | Respiratory System | −$53.0 | −7.7% | −$52.1 | −7.6% | −$12.8 | −1.9% | −$95.6 | −13.9%
Standardized Contracts | Ophthalmology | −$113.5 | −9.5% | −$74.5 | −6.2% | −$26.5 | −2.2% | −$168.5 | −14.1%
Standardized Contracts | Pain and Anesthesia | −$152.8 | −8.7% | −$136.5 | −7.8% | −$38.5 | −2.2% | −$260.2 | −14.8%
Standardized Contracts | Immunomodulation | −$47.8 | −7.9% | −$39.5 | −6.5% | −$12.3 | −2.0% | −$79.7 | −13.2%
Standardized Contracts | All Therapeutic Areas | −$78.0 | −8.9% | −$66.3 | −7.5% | −$19.9 | −2.3% | −$130.3 | −14.8%

[a] The sum of changes from baseline for individual elements do not sum to total change due to rounding and the fact that some impacts when examined jointly can have offsetting effects.

8 DASH specifically captures “level of evidence” studies: pivotal and supportive studies used to support the regulatory approval of the drug. This is often a subset of the total number of trials conducted and/or submitted in the marketing application. One can then argue that since FDA DASH captures “real” applications and is a better reflection of the types of studies included in applications, then having fewer studies is not necessarily a weakness/limitation.