# 4 DATA SOURCES

We describe the primary data sources used in the modeling in the following sections. In addition to these data sources, we also used published studies to support our parameter estimates and assumptions. These are noted in those sections where applicable.

## 4.1 MEDIDATA SOLUTIONS DATA

We used a custom tabulation from three proprietary databases on clinical trial costs, which are offered by Medidata Solutions:^6^

▪ Medidata Grants Manager^®^ (PICAS^®^ database) – PICAS provides industry-wide negotiated site cost information. It is a database of negotiated investigator grants— it includes more than 250,000 grants and contracts and 27,000 protocols in over 1,400 indications—that provides benchmarked costs typically used for clinical trial budget planning.
▪ Medidata CRO Contractor^®^ (CROCAS^®^ database) – The CROCAS database contains thousands of negotiated outsourcing contracts. It includes comprehensive data from CRO contracts—detailed across such dimensions as therapeutic area, phase, and geography.
▪ Medidata Insights^™^ – Medidata Insights is the turnkey clinical analytics solution that provides advanced visualization of clinical operational performance metrics alongside company and industry benchmarks. The Insights metrics warehouse is comprised of data from more than 7,000 studies gathered seamlessly from over 120 clinical trial sponsors.

The data tabulation, referred to as Medidata hereinafter, covered the period 2004 through 2012 and included average expenditures for the full range of cost elements associated with clinical trials, including cost of IRB approvals, cost of protocols, patient recruitment costs, and administrative staff costs among others by therapeutic area.^7^

## 4.2 IQVIA GRANTPLAN^®^

IQVIA’s GrantPlan is a large database of current clinical investigator budgets from 62 countries. The database contains cost data compiled from final negotiated budgets between sponsors and investigator sites at the procedure, cost per visit, and cost per patient levels from countries involved in drug testing throughout North America, Europe, Asia, and Latin America. The database includes cost information from 48 sponsors and 12 CROs that conduct 76 percent of all global clinical trials. We obtained a custom tabulation from this proprietary database that provided cost per patient estimates by therapeutic area, phase, and country along with applicable overhead benchmarks covering the period from 2015 through 2019.

## 4.3 CUTTING EDGE (CE) REPORT ON CLINICAL DEVELOPMENT AND TRIAL OPERATIONS

Cutting Edge (CE), LLC periodically publishes a study on clinical development and trial operations protocol design and cost per patient benchmarks. CE collects the data for their study via a survey supplemented with interviews. CE’s 2013 report contained information gathered from over 140 clinical trials conducted by pharmaceutical and biotechnology companies as well as CROs of varying sizes and geographic locations (Cutting Edge Information, LLC, 2013). We used the cost per patient estimates reported in their 2013 publication across different therapeutic areas.

## 4.4 CLINICALTRIALS.GOV DATA

Clinicaltrials.gov is a registry launched in September 2000 to provide protocol and results information on clinical trials conducted in the U.S. and around the world. Clinicaltrials.gov data are updated daily and provide information on such parameters as study start and end dates and number of patients enrolled for the registered studies that are relevant for our model. We used a snapshot of the clinicaltrials.gov data downloaded on June 24, 2020 (i.e., the monthly archived data file titled, “20200624_pip-delimited-export.zip”) through the Clinical Trials Transformation Initiative’s (CTTI) Access to Aggregate Content of ClinicalTrials.gov (AACT) initiative. The database included 343,555 unique NCT IDs.

Next, we subset the downloaded data to contain only those studies that 1) were completed between January 1, 2014 through June 24, 2020; 2) were interventional in nature ; 3) where the intervention was a drug; and 4) had a category that corresponded to one or more of the 13 therapeutic areas in our model (Table 1). The selection criteria resulted in a total of 10,307 unique research studies. Of these studies, we excluded 13 percent (1,303 studies) because they were either an early phase 1 study (195 out of 1.303 studies) or did not specify the study phase (1,108 out of 1,303 studies). Of the remaining 9,004 studies, 25 percent were Phase 1, 30 percent were Phase 2, 23 percent were Phase 3, and 22 percent were Phase 4.

## 4.5 FDA CDER DATA ANALYSIS SEARCH HOST (DASH) DATA

Data Analysis Search Host (DASH) is a database built by FDA CDER for monitoring and querying the progress of applications submitted for CDER review. DASH consolidates key data—including details about the medical products themselves as well as every stage of development through FDA’s regulatory process—for INDs, NDAs, and BLAs from 2007 to present. While the database contains nearly 100 fields associated with each new molecular entity (NME) NDA and original BLA, not all data can be shared publicly. Thus, we worked with CDER to build a custom tabulation of select fields and appropriate level of aggregation for use in our model. Our custom query covered data 2007 through August 2017 and included approved products only. For products with multiple review cycles, only data from the most recent review cycle was provided.

Table 1 Model Therapeutic Areas Mapped onto Clinicaltrials.gov Therapeutic Categories

Model Therapeutic Area | Clinicaltrials.gov Therapeutic Category
Anti-Infective | Bacterial and Fungal Diseases
Anti-Infective | Parasitic Diseases
Anti-Infective | Viral Diseases
Cardiovascular | Heart and Blood Diseases
Central Nervous System | Behaviors and Mental Disorders
Central Nervous System | Nervous System Diseases
Central Nervous System | Substance Related Disorders
Dermatology | Skin and Connective Tissue Diseases
Endocrine | Gland and Hormone Related Diseases
Endocrine | Nutritional and Metabolic Diseases
Gastrointestinal | Digestive System Diseases
Genitourinary System | Urinary Tract, Sexual Organs, and Pregnancy Conditions
Hematology | Blood and Lymph Conditions
Immunomodulation | Immune System Diseases
Immunomodulation | Muscle, Bone, and Cartilage Diseases
Oncology | Cancers and Other Neoplasms
Ophthalmology | Eye Diseases
Pain and Anesthesia | ^[a]^
Respiratory System | Respiratory Tract (Lung and Bronchial) Diseases
Not Mapped | Diseases and Abnormalities at or Before Birth
Not Mapped | Disorders of Environmental Origin
Not Mapped | Ear, Nose, and Throat Diseases
Not Mapped | Mouth and Tooth Diseases
Not Mapped | Occupational Diseases
Not Mapped | Symptoms and General Pathology
Not Mapped | Wounds and Injuries

[a] None of the broad therapeutic areas listed in the “category” field of clinicaltrials.gov directly corresponded to “pain and anesthesia.” To include those studies, we searched for those studies that mentioned “pain” and/or “anesthesia” in the “condition” field and mapped them onto our model’s pain and anesthesia therapeutic area.

6 Medidata databases contain numerous data elements derived from actual negotiated contracts, and these resources are widely used by medical product companies, contract research organizations (CROs), and academic researchers to identify prevailing rates for trial planning, budget development, and grant negotiation (Medidata Solutions, 2012).

7 More information on the data along with assumptions used to extrapolate certain variables are available in (Sertkaya, et al., 2016).