# 3 ANALYTICAL FRAMEWORK

To be able to assess the impact of clinical trial strategies noted in Section 1 above on development costs, we first need estimates of baseline development costs for drugs. We use the method by DiMasi et al. (2016; 1991) that takes account of the cost of failures and cost of capital. The methodology is described in detail in DiMasi et al. (1991); thus, we only summarize it below.

Drug development progresses in phases from early research and development to animal testing, to testing in humans, to regulatory submission for marketing approval and to post-approval studies. For the purpose of this analysis, we broke down the overall development of a drug as shown in Figure 1, into six distinct phases, including 1—non-clinical, which includes all steps in between target discovery (Stage A) and FDA IND approval (Stage F), 2—Phase 1, 3— Phase 2, 4—Phase 3, 5—FDA review, and 6—Phase 4. If the cash outlay (also known as out-of-pocket cost) associated with a given phase i is C_i_, then the expected cost, E(C_i_), that incorporates failures can be computed by dividing this cost by the transition success probability from phase i to launch, p_i_, i.e.,

E (C_i_) = (C_i_)/(p_i_) Equation 1. The expected value of C sub i, denoted E of C sub i, equals C sub i divided by p sub i. (1)

Assuming that phase costs are distributed uniformly over the length of the phase, t_i_, the capitalized cost, CC_i_, that accounts for the opportunity cost of the investment in the drug is given by:

C C_i_ = ∫_t_i , e__^t_i , b_^ ((C_i_)/(t_i_)) (e^r t^) d t Equation 2. CC sub i equals the integral from t sub i,e to t sub i,b of the quantity (C sub i divided by t sub i) times e raised to the power of r times t, with respect to t. (2)

where r is the cost of capital that captures the time value effect; t_i,b_ is the time from the beginning, b, of the given phase to product launch, and t_i,e_ is the time from the end, e, of the given phase to product launch. The above equation then becomes:

C C_i_ = [((C_i_ / t_i_))/(r)] (e^r t_i , b_^ − e^r t_i , e_^) Equation 3. CC sub i equals the quantity (C sub i divided by t sub i), divided by r, multiplied by the difference between e raised to the power of r times t sub i,b and e raised to the power of r times t sub i,e. (3)

Given the above equations, we can then compute the expected capitalized cost of phase i that accounts for the cost of failures as well as the cost of capital as:

E (C C_i_) = (C C_i_)/(p_i_) Equation 4. The expected value of CC sub i, denoted E of CC sub i, equals CC sub i divided by p sub i. (4)

Then the total expected capitalized cost of development for a drug, E(CC), is the sum of the expected capitalized cost of each phase i,

E ( C C ) = ∑_i = 1_^n^ E (C C_i_) Equation 5. The expected value of CC, denoted E of CC, equals the sum from i equals 1 to n of the expected value of CC sub i. (5)

where i = non-clinical, Phase 1, Phase 2, Phase 3, FDA review, and Phase 4.

For example, suppose the total out of pocket cash outlay for Phase 2 is $5.0 million for a given drug x and the probability of the drug making it to market given that it is in Phase 2 is 40 percent, then the expected cost of Phase 2, E(C_2_), that accounts for failures is $12.5 million, i.e.,

E (C_2_) = (C_2_)/(p_2_) = ($ 5.0)/(0.40) = $ 12.5 million Equation 6. The expected value of C sub 2, denoted E of C sub 2, equals C sub 2 divided by p sub 2, which is $5.0 divided by 0.40, or $12.5 million. (6)

If we further assume that the cost of capital, r, is 1 percent per month (i.e., 12 percent per annum) and that Phase 2 lasts 35 months (t_2_ = 35) begins 105 months before drug launch ( t_2_^b^ = 105 ) and ends 71 months before drug launch ( t_2_^e^ = 71 ) then the capitalized cost of Phase 2, CC_2_, that accounts for the opportunity cost of the investment in drug x is $11.8 million, i.e.,

C C_2_ = [((C_2_ / t_2_))/(r)] (e^r t_2 , b_^ − e^r t_2 , e_^) = [($ 5.0 / 35)/(0.01)] (e^0.01 × 105^ − e^0.01 × 71^) = $ 11.8 million Equation 7. CC sub 2 equals the quantity (C sub 2 divided by t sub 2), further divided by r, multiplied by the difference between e raised to the power of r times t sub 2,b and e raised to the power of r times t sub 2,e. Numerically, this is calculated as [($5.0 ÷ 35) ÷ 0.01] times (e to the 0.01 × 105 minus e to the 0.01 × 71), which equals $11.8 million. (7)

Using the above equations, we can compute the expected capitalized cost of Phase 2, E(CC_2_), as $29.4 million:

E (C C_2_) = (C C_2_)/(p_2_) = ($ 11.8)/(0.40) = $ 29.4 million Equation 8. The expected value of CC sub 2, denoted E of CC sub 2, equals CC sub 2 divided by p sub 2. Numerically, this is $11.8 million divided by 0.40, which equals $29.4 million. (8)

We use this approach to compute the total expected capitalized cost of developing a drug as described in the sections below.