# 2 STUDY OBJECTIVE

The primary aim of this study is to evaluate the potential savings from implementing the strategies identified above. To facilitate this evaluation, an analytical model that accounts for the cost, duration, the probability of successfully transitioning from one development stage to the next depicted in Figure 1 is needed. Thus, our secondary objective is the development of such a model using public and private data sources.