# 1 INTRODUCTION

There is ongoing debate on how to spur innovation of new medical products while controlling health care costs. Part of this debate has focused on the rising costs of bringing a medical product to market. Clinical trials constitute a major portion of the overall duration and cost of medical product development.^2^ According to one study, the clinical phase of drug development lasts an average of around 95 months compared to 31 months for the non-clinical phase and accounts for 69 percent of R&D costs (DiMasi, et al., 2016). The same (2016) study estimates the average cost of clinical trials for an FDA-approved new drug at $339.3 million in 2013 dollars overall with Phase 1 accounting for 7.5 percent ($25.3 million), Phase 2 for 17.3 percent ($58.6 million), and Phase 3 for 75.3 percent ($255.4 million). Although there is disagreement on the magnitude of these clinical trial costs,^3^ most agree that they comprise a large portion of overall development costs for drugs.

Figure 1 depicts a stylized model of the drug development process from conception through post marketing activities. The initial phase of development begins with the exploratory stage which includes identification and validation of a “druggable” target for a specific disease (A—Target Discovery in Figure 1).^4^ Once a target candidate is identified and validated, the developer uses screening approaches to identify a “hit” compound (i.e., a compound that interacts with the target of interest) using such strategies as high-throughput screening, phenotypic screening, virtual screening, fragment-based screening and structure-based design (B—Hit Generation) (Lansdowne, 2020). Next, the developer works on refining these “hits” to optimize their pharmacokinetic properties while also investigating their “off-target” interactions to get a sense of potential adverse effects (C—Lead Identification). After optimizing the lead compound (D—Lead Optimization), preclinical in-vitro and in-vivo testing (E—Animal Testing) is conducted to begin accumulating evidence of the compound’s biological affect (U.S. Food and Drug Administration, 2018b). The developer then uses animal models to answer such questions as “What does the drug do to the body?, What does the body do to the drug?, and It is potent, but is it safe?” (Lansdowne, 2020).

Upon completion of early discovery and preclinical testing (Stages A through E in Figure 1), the developer must submit an investigational new drug (IND) application to the FDA before clinical testing on human subjects may begin (F—FDA IND Submission). The IND application includes “…animal study data and toxicity (side effects that cause great harm) data; manufacturing information; clinical protocols (study plans) for studies to be conducted; data from any prior human research; and information about the investigator.” (U.S. Food and Drug Administration, 2018b). FDA reviews the IND and must inform the sponsor of any issues that would delay or suspend the proposed clinical investigation at or before 30 days from receipt of the IND. The sponsor may begin testing on humans under the specified IND number, once FDA determines that there are no outstanding issues in the information provided in the original IND that would delay or suspend the proposed clinical study.

Figure 1 Overview of Drug Development

The figure describes the step-wise drug development process which includes the following steps in order: target discovery, hit generation, lead identification, lead optimization, animal testing, FDA IND submission, Phase 1, Phase 2, Phase 3, FDA NDA/BLA application, market launch, and Phase 4.

Once clinical investigation under the sponsor’s IND is allowed to proceed, the sponsor may then begin the next phase in development, the clinical stage (Stages G through I in Figure 1), which usually consists of three clinical phases. Phase 1 clinical studies test for safety and dosing among a small group (20 to 100) of closely monitored subjects who are either healthy or have the disease or condition. Phase 2 studies enroll several hundred subjects that have the disease or condition and provide additional information on safety and dosing as well as early evidence of efficacy and adverse events. Phase 3 studies enroll 300 to 3,000 or more subjects with the disease or condition and provide a thorough assessment of safety and efficacy of the are usually demonstrated through well-controlled randomized and double-blind trials. Occasionally, the sponsor must conduct a large-scale noninferiority study for a new drug that is the same general type as a drug already on the market (U.S. Food and Drug Administration, 2016a).

Upon completion of clinical trials to support approval, the developer then submits a New Drug Application (NDA) to FDA’s Center for Drug Evaluation and Research (CDER) if the drug is a pharmaceutical or a Biologics License Application (BLA) to CDER or FDA’s Center for Biologics Evaluation and Research (CBER) if the drug is a biologic.^5^ The application must demonstrate safety and efficacy, as well as an acceptable manufacturing process, which is confirmed through a manufacturing facility inspection. Once the appropriate center conducts a scientific review, the applicable FDA product advisory committee may be asked to reviews and comment on the benefit-to-risk ratio of the drug for FDA’s consideration in taking an action (U.S. Food and Drug Administration, 2020b). An approved marketing application allows the developer to bring the drug to the market for one or more labeled indication(s). Once on the market, the drug enters the post-marketing stage, which may include conducting Phase 4 studies to investigate rare cases and to monitor adverse events; studying the safety and efficacy of the drug on pediatric populations; and submitting batch manufacturing samples to FDA for potency, safety, and purity tests.

Given the relatively large contribution of clinical phase to overall development costs, strategies with potential to reduce time and cost of conducting drug clinical trials are important. In a previous study, we identified several promising strategies with potential to improve drug development efficiency and hence reduce costs (Eastern Research Group, Inc., 2022). These strategies included:

▪ Mobile technologies—Mobile technologies can include cell phones, wearable trackers, and other devices that capture data directly from patients. Electronic data capture means capturing study data in electronic format. The strategy could entail encouraging the use of mobile and other technologies in clinical trials and the development process as a whole and clarifying requirements around their use.
▪ Simplified clinical trial protocols and reduced amendments—The strategy could entail encouraging sponsors to simplify clinical trial protocols, where possible, ensuring that they have a clear understanding of what is required by FDA and what is superfluous.
▪ Reduced source data verification (SDV)—Source data verification is the process of comparing data collected throughout the clinical trial to the original source of information to verify data integrity. The strategy could entail engaging sponsors in discussions on the topic of data and site monitoring to ensure that they are aware of the FDA guidance stating that 100 percent source data verification is not required, as well as continuing to educate reviewers on this policy.
▪ Improvements in FDA review efficiency and interactions—The strategy could entail providing more opportunity to identify, discuss, and resolve substantive issues during the review, continuing to educate FDA reviewers on changes in FDA policy, and providing more transparency about what endpoints are required. However, the strategy does not account for the additional resource burden on FDA associated with implementing these strategies.
▪ Staged approval—Staged approval could entail granting provisional marketing approval to market a drug vaccine after safety and basic efficacy have been shown, and then continuing to collect additional safety and efficacy data. This would reduce the threshold for initial approval, perhaps with a limited patient population, and then gradually expand it as more data are collected.
▪ Biomarkers as surrogate endpoints—Biomarkers as surrogate endpoints are biological indicators that may correlate with the desired clinical endpoint, for example when it would take a long time for the clinical endpoint to become evident. The strategy could entail clarifying the path to biomarker validation or encouraging collaboration between academics, public entities, and industry to develop and validate biomarkers for use as surrogate endpoints.
▪ Electronic health records—EHRs, used here as being synonymous with electronic medical records (EMRs), are digital versions of the data collected when a patient visits a healthcare provider’s office. The strategy could entail encouraging sponsors to use EHRs for patient and physician recruitment or to collect clinical endpoints.
▪ Patient registries—A patient registry is an organized system that uses observational study methods to collect uniform data to evaluate specified outcomes of a disease or condition for a population. Registries include those established by a patient organization for a particular disease as well as registries that are sometimes established by the manufacturer and used as a post-marketing study. The strategy could entail encouraging sponsors to use registry data for patient and physician recruitment or to collect clinical endpoints for use in a clinical trial, where possible.
▪ Adaptive design—An adaptive design allows modifications to the trial and/or statistical procedures of the trial after its initiation without undermining its validity and integrity. The strategy could entail clarifying FDA’s policies on whether certain types of adaptive trial design are acceptable and encouraging their use.
▪ Standardized contracts—Standardized contracts are contract templates for use in sponsor-initiated multi-site trials, intended to reduce the complexity and duration of contract negotiations for clinical trial studies. The strategy could entail encouraging the use of master contracts and standardized contracts or compiling existing resources into a central location.

2 We acknowledge that strategies for the identification of new compounds (e.g., high-throughput screening, in silico testing, etc.) in early drug discovery could also have sizable impacts on total development costs. However, such strategies were deemed out of scope for this study given our focus on the clinical research phase.

3 A 2018 study by Moore, et al. found that the median pivotal trial costs for new drugs approved by FDA during the 2015-2016 period was much lower than the frequently-cited estimates. After examining 138 pivotal trials that covered 59 different drugs, the authors estimated the median cost of a pivotal trial at $19 million (interquartile range, $12.2 million-$33.1 million) as opposed to the $255.4 million estimate reported in DiMasi, et al. (2016). A more recent follow-up study conducted by the same group estimated the median cost of pivotal trials for oncology drugs at $31.7 million (interquartile range = $17.0-$60.4 million) (Hsiue, et al., 2020). The term pivotal trial is often associated with a Phase 3 study but can also refer to a Phase 2 study under limited circumstances.

4 A target is deemed “druggable” if its activity can be altered by a therapeutic agent (Lansdowne, 2020).

5 In 2003, FDA transferred some of the therapeutic biological products under CBER’s purview to CDER, These products include “…monoclonal antibodies for in vivo use; proteins intended for therapeutic use, including cytokines (e.g. interferons), enzymes (e.g. thrombolytics), and other novel proteins, except for those that are specifically assigned to CBER (e.g., vaccines and blood products); Immunomodulators (non-vaccine and non-allergenic products intended to treat disease by inhibiting or modifying a pre-existing immune response); [and] growth factors, cytokines, and monoclonal antibodies intended to mobilize, stimulate, decrease or otherwise alter the production of hematopoietic cells in vivo” (U.S. Food and Drug Administration, 2018j).