# APPENDIX A DETAILED EXPERT ESTIMATES OF STRATEGY IMPACTS ON COST, DURATION, AND PROBABILITY OF PHASE TRANSITION SUCCESS FOR DRUGS, BY THERAPEUTIC AREA

Therapeutic Area | Phase | Element | Mobile Technologies | Simplified Clinical Trial Protocols and Reduced Amendments | Reduced SDV | Improvements in FDA Review Efficiency and Interactions | Staged Approval | Biomarkers as Surrogate Endpoints | Electronic Health Records | Patient Registries | Adaptive Design | Standardized Contracts
Anti-Infective | Non-clinical | Cost | −1% | −3% | −1% | −1% | 0% | −5% | −1% | 0% | 0% | −4%
Anti-Infective | Non-clinical | Success Likelihood | 0% | 0% | 0% | 3% | 0% | 5% | 0% | 0% | 0% | 0%
Anti-Infective | Non-clinical | Duration | 0% | −2% | 0% | 0% | 0% | −2% | −1% | 0% | 0% | −5%
Anti-Infective | Phase 1 | Cost | −2% | −5% | −4% | −2% | 0% | −3% | −1% | −4% | 5% | −5%
Anti-Infective | Phase 1 | Success Likelihood | 1% | 1% | 0% | 2% | 1% | 5% | 1% | 0% | 4% | 0%
Anti-Infective | Phase 1 | Duration | −2% | −5% | −2% | −2% | 0% | −2% | −3% | −5% | 6% | −8%
Anti-Infective | Phase 2 | Cost | −7% | −9% | −8% | −4% | −1% | −5% | −5% | −4% | −2% | −6%
Anti-Infective | Phase 2 | Success Likelihood | 4% | 3% | 0% | 9% | 6% | 2% | 1% | 0% | 12% | 0%
Anti-Infective | Phase 2 | Duration | −5% | −7% | −4% | −3% | −1% | −6% | −4% | −5% | 0% | −8%
Anti-Infective | Phase 3 | Cost | −13% | −12% | −15% | −10% | −10% | −9% | −9% | −5% | −8% | −8%
Anti-Infective | Phase 3 | Success Likelihood | 4% | 5% | 0% | 13% | 5% | 5% | 2% | 1% | 9% | 0%
Anti-Infective | Phase 3 | Duration | −8% | −8% | −9% | −9% | −8% | −7% | −8% | −5% | −9% | −10%
Anti-Infective | Phase 3L | Cost | −13% | −12% | −15% | −10% | −10% | −9% | −9% | −7% | −8% | −8%
Anti-Infective | Phase 3L | Success Likelihood | 4% | 5% | 0% | 13% | 5% | 5% | 2% | 1% | 9% | 0%
Anti-Infective | Phase 3L | Duration | −8% | −8% | −9% | −9% | −8% | −7% | −8% | −7% | −9% | −10%
Anti-Infective | Phase 3N | Cost | −13% | −12% | −15% | −10% | −10% | −9% | −9% | −5% | −8% | −8%
Anti-Infective | Phase 3N | Success Likelihood | 4% | 5% | 0% | 13% | 5% | 5% | 2% | 1% | 9% | 0%
Anti-Infective | Phase 3N | Duration | −8% | −8% | −9% | −9% | −8% | −7% | −8% | −5% | −9% | −10%
Anti-Infective | FDA Submission | Cost | −5% | −3% | −10% | −2% | −5% | −2% | −4% | −4% | −1% | −3%
Anti-Infective | FDA Submission | Success Likelihood | 1% | 1% | 0% | 5% | 4% | 1% | 1% | 0% | 5% | 0%
Anti-Infective | FDA Submission | Duration | −1% | −3% | −6% | −1% | −4% | −2% | −6% | −4% | −2% | −5%
Anti-Infective | Phase 4 | Cost | −18% | −9% | −14% | −5% | −1% | −2% | −14% | −6% | −3% | −6%
Anti-Infective | Phase 4 | Duration | −8% | −6% | −6% | −3% | −1% | −1% | −12% | −7% | −3% | −8%
Cardiovascular | Non-clinical | Cost | −1% | −3% | −4% | −1% | 0% | −3% | −1% | 0% | 0% | −5%
Cardiovascular | Non-clinical | Success Likelihood | 0% | 0% | −5% | 3% | 0% | 4% | 0% | 0% | 0% | 1%
Cardiovascular | Non-clinical | Duration | 0% | −2% | −4% | 0% | 0% | −1% | −1% | 0% | 0% | −6%
Cardiovascular | Phase 1 | Cost | −2% | −8% | −7% | −3% | 0% | −3% | −1% | −4% | 5% | −7%
Cardiovascular | Phase 1 | Success Likelihood | 1% | 1% | −5% | 5% | 1% | 5% | 1% | 0% | 3% | 1%
Cardiovascular | Phase 1 | Duration | −2% | −5% | −5% | −3% | 0% | −1% | −4% | −4% | 5% | −8%
Cardiovascular | Phase 2 | Cost | −9% | −11% | −11% | −6% | −1% | −1% | −5% | −4% | −2% | −8%
Cardiovascular | Phase 2 | Success Likelihood | 4% | 3% | −3% | 12% | 6% | 1% | 1% | 0% | 11% | 2%
Cardiovascular | Phase 2 | Duration | −6% | −8% | −7% | −5% | −1% | −2% | −4% | −4% | 0% | −10%
Cardiovascular | Phase 3 | Cost | −14% | −16% | −18% | −12% | −10% | −4% | −8% | −5% | −7% | −10%
Cardiovascular | Phase 3 | Success Likelihood | 5% | 8% | −3% | 14% | 5% | 3% | 2% | 1% | 8% | 2%
Cardiovascular | Phase 3 | Duration | −9% | −11% | −12% | −9% | −7% | −3% | −8% | −5% | −7% | −12%
Cardiovascular | Phase 3L | Cost | −14% | −16% | −18% | −12% | −10% | −4% | −9% | −6% | −7% | −10%
Cardiovascular | Phase 3L | Success Likelihood | 5% | 8% | −3% | 14% | 5% | 3% | 2% | 1% | 8% | 2%
Cardiovascular | Phase 3L | Duration | −9% | −11% | −12% | −9% | −7% | −3% | −9% | −7% | −7% | −12%
Cardiovascular | Phase 3N | Cost | −14% | −16% | −18% | −12% | −10% | −4% | −8% | −5% | −7% | −10%
Cardiovascular | Phase 3N | Success Likelihood | 5% | 8% | −3% | 14% | 5% | 3% | 2% | 1% | 8% | 2%
Cardiovascular | Phase 3N | Duration | −9% | −11% | −12% | −9% | −7% | −3% | −8% | −5% | −7% | −12%
Cardiovascular | FDA Submission | Cost | −6% | −6% | −13% | −5% | −4% | −2% | −5% | −3% | −2% | −6%
Cardiovascular | FDA Submission | Success Likelihood | 2% | 4% | −3% | 5% | 3% | 1% | 1% | 0% | 5% | 1%
Cardiovascular | FDA Submission | Duration | −2% | −6% | −9% | −2% | −4% | −2% | −7% | −4% | −2% | −7%
Cardiovascular | Phase 4 | Cost | −21% | −15% | −15% | −8% | −1% | −2% | −17% | −10% | −3% | −9%
Cardiovascular | Phase 4 | Duration | −9% | −10% | −7% | −4% | −1% | −1% | −12% | −8% | −3% | −10%
Central Nervous System | Non-clinical | Cost | −1% | −4% | −1% | −1% | 0% | −4% | −1% | 0% | 0% | −4%
Central Nervous System | Non-clinical | Success Likelihood | 0% | 0% | 0% | 4% | 0% | 5% | 0% | 0% | 0% | 0%
Central Nervous System | Non-clinical | Duration | 0% | −3% | 0% | 0% | 0% | −2% | −1% | 0% | 0% | −5%
Central Nervous System | Phase 1 | Cost | −3% | −5% | −5% | −2% | 0% | −3% | 0% | −5% | 6% | −6%
Central Nervous System | Phase 1 | Success Likelihood | 2% | 1% | 0% | 2% | 2% | 6% | 2% | 0% | 4% | 0%
Central Nervous System | Phase 1 | Duration | −3% | −5% | −2% | −2% | 0% | −2% | −3% | −5% | 7% | −7%
Central Nervous System | Phase 2 | Cost | −8% | −9% | −10% | −4% | −2% | −1% | −5% | −5% | −1% | −7%
Central Nervous System | Phase 2 | Success Likelihood | 4% | 4% | 0% | 10% | 7% | 2% | 2% | 0% | 14% | 0%
Central Nervous System | Phase 2 | Duration | −6% | −8% | −5% | −3% | −2% | −3% | −4% | −5% | 1% | −9%
Central Nervous System | Phase 3 | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −8% | −6% | −8% | −9%
Central Nervous System | Phase 3 | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 1% | 10% | 0%
Central Nervous System | Phase 3 | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −8% | −6% | −9% | −12%
Central Nervous System | Phase 3L | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −9% | −8% | −8% | −9%
Central Nervous System | Phase 3L | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 2% | 10% | 0%
Central Nervous System | Phase 3L | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −9% | −8% | −9% | −12%
Central Nervous System | Phase 3N | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −8% | −6% | −8% | −9%
Central Nervous System | Phase 3N | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 1% | 10% | 0%
Central Nervous System | Phase 3N | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −8% | −6% | −9% | −12%
Central Nervous System | FDA Submission | Cost | −6% | −3% | −12% | −2% | −5% | −3% | −5% | −4% | −1% | −3%
Central Nervous System | FDA Submission | Success Likelihood | 1% | 1% | 0% | 6% | 4% | 2% | 1% | 0% | 6% | 0%
Central Nervous System | FDA Submission | Duration | −1% | −3% | −7% | −1% | −5% | −3% | −7% | −5% | −2% | −5%
Central Nervous System | Phase 4 | Cost | −21% | −10% | −17% | −5% | −1% | −3% | −15% | −7% | −3% | −8%
Central Nervous System | Phase 4 | Duration | −9% | −7% | −7% | −3% | −1% | −2% | −13% | −8% | −3% | −9%
Dermatology | Non-clinical | Cost | −1% | −4% | −1% | −1% | 0% | −4% | −1% | 0% | 0% | −4%
Dermatology | Non-clinical | Success Likelihood | 0% | 0% | 0% | 4% | 0% | 5% | 0% | 0% | 0% | 0%
Dermatology | Non-clinical | Duration | 0% | −3% | 0% | 0% | 0% | −2% | −1% | 0% | 0% | −5%
Dermatology | Phase 1 | Cost | −3% | −5% | −5% | −2% | 0% | −3% | 0% | −5% | 6% | −6%
Dermatology | Phase 1 | Success Likelihood | 2% | 1% | 0% | 2% | 2% | 6% | 2% | 0% | 4% | 0%
Dermatology | Phase 1 | Duration | −3% | −5% | −2% | −2% | 0% | −2% | −3% | −5% | 7% | −7%
Dermatology | Phase 2 | Cost | −8% | −9% | −10% | −4% | −2% | −1% | −5% | −5% | −1% | −7%
Dermatology | Phase 2 | Success Likelihood | 4% | 4% | 0% | 10% | 7% | 2% | 2% | 0% | 14% | 0%
Dermatology | Phase 2 | Duration | −6% | −8% | −5% | −3% | −2% | −3% | −4% | −5% | 1% | −9%
Dermatology | Phase 3 | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −8% | −6% | −8% | −9%
Dermatology | Phase 3 | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 1% | 10% | 0%
Dermatology | Phase 3 | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −8% | −6% | −9% | −12%
Dermatology | Phase 3L | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −9% | −8% | −8% | −9%
Dermatology | Phase 3L | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 2% | 10% | 0%
Dermatology | Phase 3L | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −9% | −8% | −9% | −12%
Dermatology | Phase 3N | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −8% | −6% | −8% | −9%
Dermatology | Phase 3N | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 1% | 10% | 0%
Dermatology | Phase 3N | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −8% | −6% | −9% | −12%
Dermatology | FDA Submission | Cost | −6% | −3% | −12% | −2% | −5% | −3% | −5% | −4% | −1% | −3%
Dermatology | FDA Submission | Success Likelihood | 1% | 1% | 0% | 6% | 4% | 2% | 1% | 0% | 6% | 0%
Dermatology | FDA Submission | Duration | −1% | −3% | −7% | −1% | −5% | −3% | −7% | −5% | −2% | −5%
Dermatology | Phase 4 | Cost | −21% | −10% | −17% | −5% | −1% | −3% | −15% | −7% | −3% | −8%
Dermatology | Phase 4 | Duration | −9% | −7% | −7% | −3% | −1% | −2% | −13% | −8% | −3% | −9%
Endocrine | Non-clinical | Cost | −1% | −3% | −1% | −1% | 0% | −4% | −1% | 0% | 0% | −4%
Endocrine | Non-clinical | Success Likelihood | 0% | 0% | 0% | 3% | 0% | 5% | 0% | 0% | 0% | 0%
Endocrine | Non-clinical | Duration | 0% | −2% | 0% | 0% | 0% | −2% | −1% | 0% | 0% | −5%
Endocrine | Phase 1 | Cost | −2% | −7% | −5% | −2% | 0% | −3% | −1% | −5% | 5% | −5%
Endocrine | Phase 1 | Success Likelihood | 2% | 1% | 0% | 2% | 2% | 5% | 2% | 0% | 4% | 0%
Endocrine | Phase 1 | Duration | −2% | −6% | −2% | −2% | 0% | −2% | −5% | −5% | 6% | −7%
Endocrine | Phase 2 | Cost | −9% | −11% | −9% | −5% | −2% | −1% | −6% | −5% | −2% | −7%
Endocrine | Phase 2 | Success Likelihood | 5% | 3% | 0% | 10% | 7% | 2% | 2% | 0% | 13% | 0%
Endocrine | Phase 2 | Duration | −7% | −9% | −5% | −4% | −2% | −2% | −5% | −5% | 1% | −9%
Endocrine | Phase 3 | Cost | −15% | −14% | −17% | −12% | −11% | −5% | −10% | −6% | −8% | −9%
Endocrine | Phase 3 | Success Likelihood | 6% | 6% | 0% | 12% | 6% | 4% | 2% | 1% | 9% | 0%
Endocrine | Phase 3 | Duration | −10% | −10% | −10% | −9% | −8% | −3% | −9% | −6% | −8% | −12%
Endocrine | Phase 3L | Cost | −15% | −14% | −17% | −12% | −11% | −5% | −10% | −7% | −8% | −9%
Endocrine | Phase 3L | Success Likelihood | 6% | 6% | 0% | 12% | 6% | 4% | 2% | 2% | 9% | 0%
Endocrine | Phase 3L | Duration | −10% | −10% | −10% | −9% | −8% | −3% | −10% | −8% | −8% | −12%
Endocrine | Phase 3N | Cost | −15% | −14% | −17% | −12% | −11% | −5% | −10% | −6% | −8% | −9%
Endocrine | Phase 3N | Success Likelihood | 6% | 6% | 0% | 12% | 6% | 4% | 2% | 1% | 9% | 0%
Endocrine | Phase 3N | Duration | −10% | −10% | −10% | −9% | −8% | −3% | −9% | −6% | −8% | −12%
Endocrine | FDA Submission | Cost | −7% | −5% | −11% | −5% | −5% | −2% | −6% | −4% | −2% | −4%
Endocrine | FDA Submission | Success Likelihood | 2% | 1% | 0% | 5% | 3% | 2% | 1% | 0% | 5% | 0%
Endocrine | FDA Submission | Duration | −3% | −4% | −7% | −3% | −5% | −2% | −8% | −4% | −2% | −6%
Endocrine | Phase 4 | Cost | −22% | −11% | −15% | −9% | −1% | −2% | −20% | −11% | −3% | −8%
Endocrine | Phase 4 | Duration | −10% | −8% | −7% | −5% | −1% | −2% | −14% | −9% | −3% | −9%
Gastrointestinal | Non-clinical | Cost | −1% | −4% | −1% | −1% | 0% | −4% | −1% | 0% | 0% | −4%
Gastrointestinal | Non-clinical | Success Likelihood | 0% | 0% | 0% | 4% | 0% | 5% | 0% | 0% | 0% | 0%
Gastrointestinal | Non-clinical | Duration | 0% | −3% | 0% | 0% | 0% | −2% | −1% | 0% | 0% | −5%
Gastrointestinal | Phase 1 | Cost | −3% | −5% | −5% | −2% | 0% | −3% | 0% | −5% | 6% | −6%
Gastrointestinal | Phase 1 | Success Likelihood | 2% | 1% | 0% | 2% | 2% | 6% | 2% | 0% | 4% | 0%
Gastrointestinal | Phase 1 | Duration | −3% | −5% | −2% | −2% | 0% | −2% | −3% | −5% | 7% | −7%
Gastrointestinal | Phase 2 | Cost | −8% | −9% | −10% | −4% | −2% | −1% | −5% | −5% | −1% | −7%
Gastrointestinal | Phase 2 | Success Likelihood | 4% | 4% | 0% | 10% | 7% | 2% | 2% | 0% | 14% | 0%
Gastrointestinal | Phase 2 | Duration | −6% | −8% | −5% | −3% | −2% | −3% | −4% | −5% | 1% | −9%
Gastrointestinal | Phase 3 | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −8% | −6% | −8% | −9%
Gastrointestinal | Phase 3 | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 1% | 10% | 0%
Gastrointestinal | Phase 3 | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −8% | −6% | −9% | −12%
Gastrointestinal | Phase 3L | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −9% | −8% | −8% | −9%
Gastrointestinal | Phase 3L | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 2% | 10% | 0%
Gastrointestinal | Phase 3L | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −9% | −8% | −9% | −12%
Gastrointestinal | Phase 3N | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −8% | −6% | −8% | −9%
Gastrointestinal | Phase 3N | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 1% | 10% | 0%
Gastrointestinal | Phase 3N | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −8% | −6% | −9% | −12%
Gastrointestinal | FDA Submission | Cost | −6% | −3% | −12% | −2% | −5% | −3% | −5% | −4% | −1% | −3%
Gastrointestinal | FDA Submission | Success Likelihood | 1% | 1% | 0% | 6% | 4% | 2% | 1% | 0% | 6% | 0%
Gastrointestinal | FDA Submission | Duration | −1% | −3% | −7% | −1% | −5% | −3% | −7% | −5% | −2% | −5%
Gastrointestinal | Phase 4 | Cost | −21% | −10% | −17% | −5% | −1% | −3% | −15% | −7% | −3% | −8%
Gastrointestinal | Phase 4 | Duration | −9% | −7% | −7% | −3% | −1% | −2% | −13% | −8% | −3% | −9%
Genitourinary System | Non-clinical | Cost | −1% | −4% | −1% | −1% | 0% | −4% | −1% | 0% | 0% | −4%
Genitourinary System | Non-clinical | Success Likelihood | 0% | 0% | 0% | 4% | 0% | 5% | 0% | 0% | 0% | 0%
Genitourinary System | Non-clinical | Duration | 0% | −3% | 0% | 0% | 0% | −2% | −1% | 0% | 0% | −5%
Genitourinary System | Phase 1 | Cost | −3% | −5% | −5% | −2% | 0% | −3% | 0% | −5% | 6% | −6%
Genitourinary System | Phase 1 | Success Likelihood | 2% | 1% | 0% | 2% | 2% | 6% | 2% | 0% | 4% | 0%
Genitourinary System | Phase 1 | Duration | −3% | −5% | −2% | −2% | 0% | −2% | −3% | −5% | 7% | −7%
Genitourinary System | Phase 2 | Cost | −8% | −9% | −10% | −4% | −2% | −1% | −5% | −5% | −1% | −7%
Genitourinary System | Phase 2 | Success Likelihood | 4% | 4% | 0% | 10% | 7% | 2% | 2% | 0% | 14% | 0%
Genitourinary System | Phase 2 | Duration | −6% | −8% | −5% | −3% | −2% | −3% | −4% | −5% | 1% | −9%
Genitourinary System | Phase 3 | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −8% | −6% | −8% | −9%
Genitourinary System | Phase 3 | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 1% | 10% | 0%
Genitourinary System | Phase 3 | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −8% | −6% | −9% | −12%
Genitourinary System | Phase 3L | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −9% | −8% | −8% | −9%
Genitourinary System | Phase 3L | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 2% | 10% | 0%
Genitourinary System | Phase 3L | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −9% | −8% | −9% | −12%
Genitourinary System | Phase 3N | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −8% | −6% | −8% | −9%
Genitourinary System | Phase 3N | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 1% | 10% | 0%
Genitourinary System | Phase 3N | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −8% | −6% | −9% | −12%
Genitourinary System | FDA Submission | Cost | −6% | −3% | −12% | −2% | −5% | −3% | −5% | −4% | −1% | −3%
Genitourinary System | FDA Submission | Success Likelihood | 1% | 1% | 0% | 6% | 4% | 2% | 1% | 0% | 6% | 0%
Genitourinary System | FDA Submission | Duration | −1% | −3% | −7% | −1% | −5% | −3% | −7% | −5% | −2% | −5%
Genitourinary System | Phase 4 | Cost | −21% | −10% | −17% | −5% | −1% | −3% | −15% | −7% | −3% | −8%
Genitourinary System | Phase 4 | Duration | −9% | −7% | −7% | −3% | −1% | −2% | −13% | −8% | −3% | −9%
Hematology | Non-clinical | Cost | −1% | −4% | −1% | −1% | 0% | −4% | −1% | 0% | 0% | −4%
Hematology | Non-clinical | Success Likelihood | 0% | 0% | 0% | 4% | 0% | 5% | 0% | 0% | 0% | 0%
Hematology | Non-clinical | Duration | 0% | −3% | 0% | 0% | 0% | −2% | −1% | 0% | 0% | −5%
Hematology | Phase 1 | Cost | −3% | −5% | −5% | −2% | 0% | −3% | 0% | −5% | 6% | −6%
Hematology | Phase 1 | Success Likelihood | 2% | 1% | 0% | 2% | 2% | 6% | 2% | 0% | 4% | 0%
Hematology | Phase 1 | Duration | −3% | −5% | −2% | −2% | 0% | −2% | −3% | −5% | 7% | −7%
Hematology | Phase 2 | Cost | −8% | −9% | −10% | −4% | −2% | −1% | −5% | −5% | −1% | −7%
Hematology | Phase 2 | Success Likelihood | 4% | 4% | 0% | 10% | 7% | 2% | 2% | 0% | 14% | 0%
Hematology | Phase 2 | Duration | −6% | −8% | −5% | −3% | −2% | −3% | −4% | −5% | 1% | −9%
Hematology | Phase 3 | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −8% | −6% | −8% | −9%
Hematology | Phase 3 | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 1% | 10% | 0%
Hematology | Phase 3 | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −8% | −6% | −9% | −12%
Hematology | Phase 3L | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −9% | −8% | −8% | −9%
Hematology | Phase 3L | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 2% | 10% | 0%
Hematology | Phase 3L | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −9% | −8% | −9% | −12%
Hematology | Phase 3N | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −8% | −6% | −8% | −9%
Hematology | Phase 3N | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 1% | 10% | 0%
Hematology | Phase 3N | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −8% | −6% | −9% | −12%
Hematology | FDA Submission | Cost | −6% | −3% | −12% | −2% | −5% | −3% | −5% | −4% | −1% | −3%
Hematology | FDA Submission | Success Likelihood | 1% | 1% | 0% | 6% | 4% | 2% | 1% | 0% | 6% | 0%
Hematology | FDA Submission | Duration | −1% | −3% | −7% | −1% | −5% | −3% | −7% | −5% | −2% | −5%
Hematology | Phase 4 | Cost | −21% | −10% | −17% | −5% | −1% | −3% | −15% | −7% | −3% | −8%
Hematology | Phase 4 | Duration | −9% | −7% | −7% | −3% | −1% | −2% | −13% | −8% | −3% | −9%
Immunomodulation | Non-clinical | Cost | −1% | −3% | −1% | −1% | 0% | −5% | −1% | 0% | 0% | −4%
Immunomodulation | Non-clinical | Success Likelihood | 0% | 0% | 0% | 3% | 0% | 5% | 0% | 0% | 0% | 0%
Immunomodulation | Non-clinical | Duration | 0% | −2% | 0% | 0% | 0% | −2% | −1% | 0% | 0% | −5%
Immunomodulation | Phase 1 | Cost | −2% | −5% | −5% | −2% | 0% | −3% | 0% | −5% | 5% | −5%
Immunomodulation | Phase 1 | Success Likelihood | 2% | 1% | 0% | 2% | 2% | 5% | 2% | 0% | 4% | 0%
Immunomodulation | Phase 1 | Duration | −2% | −5% | −2% | −2% | 0% | −2% | −3% | −5% | 6% | −7%
Immunomodulation | Phase 2 | Cost | −8% | −9% | −9% | −3% | −2% | −2% | −4% | −5% | −2% | −6%
Immunomodulation | Phase 2 | Success Likelihood | 4% | 3% | 0% | 10% | 7% | 2% | 2% | 0% | 13% | 0%
Immunomodulation | Phase 2 | Duration | −6% | −8% | −5% | −2% | −2% | −3% | −4% | −5% | 0% | −8%
Immunomodulation | Phase 3 | Cost | −14% | −13% | −17% | −9% | −11% | −5% | −8% | −6% | −8% | −8%
Immunomodulation | Phase 3 | Success Likelihood | 4% | 6% | 0% | 12% | 6% | 4% | 2% | 1% | 10% | 0%
Immunomodulation | Phase 3 | Duration | −9% | −9% | −10% | −8% | −8% | −4% | −8% | −6% | −9% | −11%
Immunomodulation | Phase 3L | Cost | −14% | −13% | −17% | −9% | −11% | −5% | −8% | −7% | −8% | −8%
Immunomodulation | Phase 3L | Success Likelihood | 4% | 6% | 0% | 12% | 6% | 4% | 2% | 2% | 10% | 0%
Immunomodulation | Phase 3L | Duration | −9% | −9% | −10% | −8% | −8% | −4% | −8% | −8% | −9% | −11%
Immunomodulation | Phase 3N | Cost | −14% | −13% | −17% | −9% | −11% | −5% | −8% | −6% | −8% | −8%
Immunomodulation | Phase 3N | Success Likelihood | 4% | 6% | 0% | 12% | 6% | 4% | 2% | 1% | 10% | 0%
Immunomodulation | Phase 3N | Duration | −9% | −9% | −10% | −8% | −8% | −4% | −8% | −6% | −9% | −11%
Immunomodulation | FDA Submission | Cost | −5% | −3% | −11% | −2% | −5% | −2% | −4% | −4% | −1% | −3%
Immunomodulation | FDA Submission | Success Likelihood | 1% | 1% | 0% | 6% | 3% | 2% | 1% | 0% | 6% | 0%
Immunomodulation | FDA Submission | Duration | −1% | −3% | −7% | −2% | −5% | −2% | −7% | −4% | −2% | −5%
Immunomodulation | Phase 4 | Cost | −19% | −10% | −15% | −5% | −1% | −2% | −13% | −7% | −3% | −7%
Immunomodulation | Phase 4 | Duration | −8% | −6% | −7% | −3% | −1% | −2% | −12% | −7% | −3% | −8%
Oncology | Non-clinical | Cost | −1% | −3% | −1% | −1% | 0% | −3% | −1% | 0% | 0% | −3%
Oncology | Non-clinical | Success Likelihood | 0% | 0% | 0% | 3% | 0% | 7% | 0% | 0% | 0% | 0%
Oncology | Non-clinical | Duration | 0% | −2% | 0% | 0% | 0% | −1% | −1% | 0% | 0% | −4%
Oncology | Phase 1 | Cost | −2% | −5% | −4% | −2% | 0% | −2% | 0% | −4% | 3% | −5%
Oncology | Phase 1 | Success Likelihood | 1% | 1% | 0% | 2% | 1% | 7% | 1% | 0% | 5% | 0%
Oncology | Phase 1 | Duration | −2% | −6% | −2% | −2% | 0% | −1% | −4% | −4% | 3% | −7%
Oncology | Phase 2 | Cost | −7% | −9% | −8% | −4% | −1% | −1% | −4% | −4% | −3% | −6%
Oncology | Phase 2 | Success Likelihood | 4% | 4% | 0% | 9% | 6% | 2% | 1% | 0% | 13% | 0%
Oncology | Phase 2 | Duration | −5% | −9% | −4% | −3% | −1% | −2% | −5% | −4% | −2% | −8%
Oncology | Phase 3 | Cost | −13% | −12% | −15% | −8% | −12% | −5% | −7% | −5% | −7% | −7%
Oncology | Phase 3 | Success Likelihood | 4% | 6% | 0% | 11% | 8% | 4% | 2% | 1% | 8% | 0%
Oncology | Phase 3 | Duration | −8% | −9% | −9% | −8% | −11% | −4% | −8% | −5% | −8% | −10%
Oncology | Phase 3L | Cost | −13% | −12% | −15% | −8% | −12% | −5% | −7% | −6% | −7% | −7%
Oncology | Phase 3L | Success Likelihood | 4% | 6% | 0% | 11% | 8% | 4% | 2% | 1% | 8% | 0%
Oncology | Phase 3L | Duration | −8% | −9% | −9% | −8% | −11% | −4% | −8% | −7% | −8% | −10%
Oncology | Phase 3N | Cost | −13% | −12% | −15% | −8% | −12% | −5% | −7% | −5% | −7% | −7%
Oncology | Phase 3N | Success Likelihood | 4% | 6% | 0% | 11% | 8% | 4% | 2% | 1% | 8% | 0%
Oncology | Phase 3N | Duration | −8% | −9% | −9% | −8% | −11% | −4% | −8% | −5% | −8% | −10%
Oncology | FDA Submission | Cost | −6% | −4% | −10% | −2% | −4% | −2% | −4% | −3% | −1% | −3%
Oncology | FDA Submission | Success Likelihood | 1% | 1% | 0% | 5% | 4% | 1% | 1% | 0% | 5% | 0%
Oncology | FDA Submission | Duration | −2% | −3% | −6% | −3% | −4% | −2% | −7% | −4% | −2% | −5%
Oncology | Phase 4 | Cost | −19% | −9% | −15% | −4% | −1% | −2% | −12% | −6% | −2% | −6%
Oncology | Phase 4 | Duration | −9% | −6% | −6% | −3% | −1% | −1% | −12% | −6% | −3% | −8%
Ophthalmology | Non-clinical | Cost | −1% | −4% | −1% | −1% | 0% | −4% | −1% | 0% | 0% | −4%
Ophthalmology | Non-clinical | Success Likelihood | 0% | 0% | 0% | 4% | 0% | 5% | 0% | 0% | 0% | 0%
Ophthalmology | Non-clinical | Duration | 0% | −3% | 0% | 0% | 0% | −2% | −1% | 0% | 0% | −5%
Ophthalmology | Phase 1 | Cost | −3% | −5% | −5% | −2% | 0% | −3% | 0% | −5% | 6% | −6%
Ophthalmology | Phase 1 | Success Likelihood | 2% | 1% | 0% | 2% | 2% | 6% | 2% | 0% | 4% | 0%
Ophthalmology | Phase 1 | Duration | −3% | −5% | −2% | −2% | 0% | −2% | −3% | −5% | 7% | −7%
Ophthalmology | Phase 2 | Cost | −8% | −9% | −10% | −4% | −2% | −1% | −5% | −5% | −1% | −7%
Ophthalmology | Phase 2 | Success Likelihood | 4% | 4% | 0% | 10% | 7% | 2% | 2% | 0% | 14% | 0%
Ophthalmology | Phase 2 | Duration | −6% | −8% | −5% | −3% | −2% | −3% | −4% | −5% | 1% | −9%
Ophthalmology | Phase 3 | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −8% | −6% | −8% | −9%
Ophthalmology | Phase 3 | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 1% | 10% | 0%
Ophthalmology | Phase 3 | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −8% | −6% | −9% | −12%
Ophthalmology | Phase 3L | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −9% | −8% | −8% | −9%
Ophthalmology | Phase 3L | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 2% | 10% | 0%
Ophthalmology | Phase 3L | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −9% | −8% | −9% | −12%
Ophthalmology | Phase 3N | Cost | −15% | −13% | −18% | −10% | −12% | −5% | −8% | −6% | −8% | −9%
Ophthalmology | Phase 3N | Success Likelihood | 5% | 6% | 0% | 13% | 6% | 4% | 3% | 1% | 10% | 0%
Ophthalmology | Phase 3N | Duration | −9% | −9% | −10% | −8% | −9% | −3% | −8% | −6% | −9% | −12%
Ophthalmology | FDA Submission | Cost | −6% | −3% | −12% | −2% | −5% | −3% | −5% | −4% | −1% | −3%
Ophthalmology | FDA Submission | Success Likelihood | 1% | 1% | 0% | 6% | 4% | 2% | 1% | 0% | 6% | 0%
Ophthalmology | FDA Submission | Duration | −1% | −3% | −7% | −1% | −5% | −3% | −7% | −5% | −2% | −5%
Ophthalmology | Phase 4 | Cost | −21% | −10% | −17% | −5% | −1% | −3% | −15% | −7% | −3% | −8%
Ophthalmology | Phase 4 | Duration | −9% | −7% | −7% | −3% | −1% | −2% | −13% | −8% | −3% | −9%
Pain and Anesthesia | Non-clinical | Cost | −1% | −3% | −1% | −1% | 0% | −4% | −1% | 0% | 0% | −4%
Pain and Anesthesia | Non-clinical | Success Likelihood | 0% | 0% | 0% | 3% | 0% | 5% | 0% | 0% | 0% | 0%
Pain and Anesthesia | Non-clinical | Duration | 0% | −2% | 0% | 0% | 0% | −2% | −1% | 0% | 0% | −5%
Pain and Anesthesia | Phase 1 | Cost | −2% | −7% | −5% | −2% | 0% | −3% | 0% | −5% | 5% | −5%
Pain and Anesthesia | Phase 1 | Success Likelihood | 2% | 1% | 0% | 2% | 2% | 5% | 2% | 0% | 4% | 0%
Pain and Anesthesia | Phase 1 | Duration | −2% | −5% | −2% | −2% | 0% | −2% | −3% | −5% | 6% | −7%
Pain and Anesthesia | Phase 2 | Cost | −9% | −11% | −9% | −3% | −2% | −1% | −4% | −5% | −1% | −6%
Pain and Anesthesia | Phase 2 | Success Likelihood | 4% | 3% | 0% | 10% | 7% | 2% | 2% | 0% | 13% | 0%
Pain and Anesthesia | Phase 2 | Duration | −6% | −8% | −5% | −2% | −2% | −2% | −4% | −5% | 1% | −8%
Pain and Anesthesia | Phase 3 | Cost | −15% | −14% | −17% | −9% | −11% | −5% | −8% | −6% | −7% | −8%
Pain and Anesthesia | Phase 3 | Success Likelihood | 4% | 6% | 0% | 12% | 6% | 4% | 2% | 1% | 9% | 0%
Pain and Anesthesia | Phase 3 | Duration | −9% | −9% | −10% | −8% | −8% | −3% | −8% | −6% | −8% | −11%
Pain and Anesthesia | Phase 3L | Cost | −15% | −14% | −17% | −9% | −11% | −5% | −8% | −7% | −7% | −8%
Pain and Anesthesia | Phase 3L | Success Likelihood | 4% | 6% | 0% | 12% | 6% | 4% | 2% | 2% | 9% | 0%
Pain and Anesthesia | Phase 3L | Duration | −9% | −9% | −10% | −8% | −8% | −3% | −8% | −8% | −8% | −11%
Pain and Anesthesia | Phase 3N | Cost | −15% | −14% | −17% | −9% | −11% | −5% | −8% | −6% | −7% | −8%
Pain and Anesthesia | Phase 3N | Success Likelihood | 4% | 6% | 0% | 12% | 6% | 4% | 2% | 1% | 9% | 0%
Pain and Anesthesia | Phase 3N | Duration | −9% | −9% | −10% | −8% | −8% | −3% | −8% | −6% | −8% | −11%
Pain and Anesthesia | FDA Submission | Cost | −5% | −3% | −11% | −2% | −5% | −2% | −4% | −4% | −1% | −3%
Pain and Anesthesia | FDA Submission | Success Likelihood | 1% | 1% | 0% | 5% | 3% | 2% | 1% | 0% | 5% | 0%
Pain and Anesthesia | FDA Submission | Duration | −1% | −3% | −7% | −1% | −5% | −2% | −7% | −4% | −2% | −5%
Pain and Anesthesia | Phase 4 | Cost | −21% | −12% | −15% | −5% | −1% | −2% | −13% | −7% | −3% | −7%
Pain and Anesthesia | Phase 4 | Duration | −8% | −7% | −7% | −3% | −1% | −2% | −12% | −7% | −3% | −8%
Respiratory | Non-clinical | Cost | −1% | −3% | −1% | −1% | 0% | −4% | −1% | 0% | 0% | −4%
Respiratory | Non-clinical | Success Likelihood | 0% | 0% | 0% | 3% | 0% | 5% | 0% | 0% | 0% | 0%
Respiratory | Non-clinical | Duration | 0% | −2% | 0% | 0% | 0% | −1% | −1% | 0% | 0% | −5%
Respiratory | Phase 1 | Cost | −3% | −6% | −5% | −2% | 0% | −3% | 0% | −4% | 4% | −5%
Respiratory | Phase 1 | Success Likelihood | 1% | 1% | 0% | 3% | 1% | 5% | 1% | 0% | 4% | 0%
Respiratory | Phase 1 | Duration | −2% | −5% | −2% | −2% | 0% | −1% | −3% | −5% | 5% | −6%
Respiratory | Phase 2 | Cost | −10% | −10% | −9% | −4% | −1% | −1% | −4% | −5% | −2% | −6%
Respiratory | Phase 2 | Success Likelihood | 4% | 3% | 0% | 10% | 6% | 1% | 1% | 0% | 13% | 0%
Respiratory | Phase 2 | Duration | −7% | −8% | −5% | −3% | −1% | −2% | −4% | −5% | 0% | −10%
Respiratory | Phase 3 | Cost | −15% | −13% | −16% | −9% | −12% | −4% | −7% | −5% | −7% | −7%
Respiratory | Phase 3 | Success Likelihood | 4% | 5% | 0% | 13% | 7% | 4% | 2% | 1% | 9% | 0%
Respiratory | Phase 3 | Duration | −10% | −8% | −9% | −8% | −10% | −3% | −8% | −6% | −8% | −13%
Respiratory | Phase 3L | Cost | −15% | −13% | −16% | −9% | −12% | −4% | −8% | −7% | −7% | −7%
Respiratory | Phase 3L | Success Likelihood | 4% | 5% | 0% | 13% | 7% | 4% | 2% | 1% | 9% | 0%
Respiratory | Phase 3L | Duration | −10% | −8% | −9% | −8% | −10% | −3% | −8% | −8% | −8% | −13%
Respiratory | Phase 3N | Cost | −15% | −13% | −16% | −9% | −12% | −4% | −7% | −5% | −7% | −7%
Respiratory | Phase 3N | Success Likelihood | 4% | 5% | 0% | 13% | 7% | 4% | 2% | 1% | 9% | 0%
Respiratory | Phase 3N | Duration | −10% | −8% | −9% | −8% | −10% | −3% | −8% | −6% | −8% | −13%
Respiratory | FDA Submission | Cost | −6% | −3% | −11% | −2% | −6% | −2% | −4% | −4% | −1% | −3%
Respiratory | FDA Submission | Success Likelihood | 1% | 1% | 0% | 6% | 5% | 1% | 1% | 0% | 5% | 0%
Respiratory | FDA Submission | Duration | −3% | −3% | −7% | −2% | −6% | −2% | −7% | −5% | −2% | −7%
Respiratory | Phase 4 | Cost | −21% | −11% | −15% | −5% | 1% | −2% | −13% | −6% | −3% | −6%
Respiratory | Phase 4 | Duration | −9% | −6% | −7% | −3% | 1% | −1% | −12% | −8% | −3% | −9%

Phase 3N = Phase 3 trial for a new drug

Phase 3L = Phase 3 trial for a label expansion

Note that sponsors conduct Phase 3 trials not just to obtain an NDA or a BLA approval from FDA for a new drug but also to expand the list of indications for an already-approved drug. Our initial discussions with experts indicated that some tended to think about the latter type of trials (i.e., Phase 3 trial for a label extension for an approved drug) when evaluating the nature of the impact for a given strategy. To ensure consistency, we elicited opinions for each type of Phase 3 trial separately.