# LIST OF ACRONYMS

ASPE: Office of The Assistant Secretary for Planning and Evaluation
BLA: Biologics license application
CROs: Contract research organization
CTTI: Clinical Trials Transformation Initiative
EHR: Electronic health record
EMR: Electronic medical record
ERG: Eastern Research Group, Inc.
FDA: Food and Drug Administration
HHS: Department of Health and Human Services
IND: Investigational new drug
IRB: Institutional review board
NDA: New drug application
NIH: National Institutes of Health
NME: New molecular entity
OCOC: Opportunity cost of capital
SDV: Source data verification