# References

Baker, A., and S. Beames. “Good CoP: What Makes a Community of Practice Successful?” Journal of Learning Design, vol. 9, no. 1, 2016, pp. 72–79. 10.5204/jld.v9i1.234.
Barbour, L., R. Armstrong, P. Condron, and C. Palermo. “Communities of Practice to Improve Public Health Outcomes: A Systematic Review.” Journal of Knowledge Management, vol. 22, no. 2, 2018, pp. 326–343. 10.1108/JKM-03-2017-0111.
Bowman, M. “6 Key Features of a Successful Community of Practice.” Learning Professional, December 2016. https://learningforward.org/journal/december-2016-issue/6-key-features-of-a-successful-community-of-practice/.
Bozarth, M. “Community of Practice Evaluation: What we Measure and Why.” West Wind Education Policy, September 23, 2013. https://westwinded.com/blog/community-of-practice-evaluation-what-we-measure-and-why/.
Centers for Disease Control and Prevention. “Applying the Knowledge to Action (K2A) Framework: Questions to Guide Planning.” U.S. Dept of Health and Human Services, 2014.
Centers for Disease Control and Prevention. “Funding for Strengthening Public Health Systems and Services through National Partnerships to Improve and Protect the Nation’s Health.” May 16, 2024. https://www.cdc.gov/public-health-gateway/php/funding/capacity-building-assistance-ot18-1802.html?CDC_AAref_Val= https://www.cdc.gov/publichealthgateway/partnerships/capacity-building-assistance-OT18–1802.html.
Edmonton Regional Learning Consortium. “Success Factors.” n.d. https://www.communityofpractice.ca/background/success-factors/. Accessed August 15, 2024.
James-McAlpine, J., S. Larkins, and C. Nagle. “Exploring the Evidence Base for Communities of Practice in Health Research and Translation: A Scoping Review.” Health Research Policy and Systems, vol. 21, 2023, article 55. 10.1186/s12961-023-01000-x.37337214
Lave, J., and E. Wenger. Situated Learning. Legitimate Peripheral Participation. Cambridge University Press, 1991.
Vital Strategies. “How to Build a Virtual Community of Practice.” September 2020. https://preventepidemics.org/wp-content/uploads/2020/09/How-to-Build-a-Virtual-Community-of-Practice.pdf.
Wenger-Trayner, E., and B. Wenger-Trayner. “Introduction to Communities of Practice: A Brief Overview of the Concept and its Uses.” June 2015. https://www.wenger-trayner.com/introduction-to-communitiesof-practice/.
Wenger, E., Trayner, B., and M. de Laat. “Promoting and Assessing Value Creation in Communities and Networks: A Conceptual Model.” Open Universiteit, Ruud de Moor Centrum, 2011. https://www.researchgate.net/publication/220040553_Promoting_and_Assessing_Value_Creation_in_Communities_and_Networks_A_Conceptual_Framework .
Wilson, K.M., T.J. Brady, and C. Lesesne. “An Organizing Framework for Translation in Public Health: The Knowledge to Action Framework.” Preventing Chronic Disease, vol. 8, no. 2, 2011, pp. 1–7. https://stacks.cdc.gov/view/cdc/4186.