# Acknowledgments

The authors thank the community of practice lead organizations; state, local, Tribal, and territorial public health staff; and federal agencies who shared their perspectives for their valuable contributions to this work. We also thank Sue Felt-Lisk, Chris Palo, and Donovan Griffin from Mathematica and Azmeh Khan from the Office of the Assistant Secretary for Planning and Evaluation (ASPE). We are especially grateful for the guidance from our project officer, Deborah Porterfield at ASPE.