# Executive Summary

The COVID-19 pandemic created an urgent need for state, Tribal, local, and territorial (STLT) public health agencies to translate knowledge and guidance into effective programs, policies, and practices. Federal agencies produced and disseminated this guidance. At the same time, nonfederal organizations (including academic institutions, philanthropic groups, and partner organizations funded by the federal government) played crucial roles in translating this guidance into actionable strategies and supporting STLT agencies in developing and implementing their COVID-19 responses. In this context, communities of practice (CoPs), traditionally valued for knowledge exchange and problem solving, emerged as essential collaborative mechanisms.

Under the Lessons Learned from the COVID-19 Pandemic contract funded by the Office of the Assistant Secretary for Planning and Evaluation (ASPE), Mathematica conducted an environmental scan to identify CoPs led by nonfederal organizations that supported STLT public health agencies and staff. The study also included in-depth interviews with 21 people, including leaders and participants from nonfederal CoPs and federal agencies that supported nonfederal CoPs or understood the CoP landscape during the COVID-19 pandemic. This study primarily explored the experience and perspectives of participants, leaders, and partners in nonfederal CoPs for STLT public health agencies. We focused on these CoPs to help understand how they aligned with or coordinated with federal efforts to reach STLT public health agencies, acknowledging that federally led CoPs and CoPs for other types of organizations took part in the effort. The goal of the study was to generate lessons and considerations for the federal government in funding, engaging, and coordinating with nonfederal CoPs in future public health emergencies.

## Key findings

The study identified three types of CoPs that played significant roles in supporting STLT public health agencies during the COVID-19 pandemic. These CoPs differed by their lead organization, and two were nonfederal:

- CoPs led by partner organizations. Partner organizations, defined as those that receive federal grants or cooperative agreements to enhance the effectiveness of the public health system, used their existing networks to tailor federal guidance to STLT needs. Existing CoPs adapted quickly by increasing how often they met, introducing new platforms and approaches for sharing COVID-19 resources, and engaging federal agencies.
- CoPs led by other types of nonfederal organizations. Led by organizations such as academic institutions and nonprofits, these CoPs filled crucial gaps in early guidance and provided unique insights because of their specialized expertise and networks. They created forums for discussing sensitive topics and challenges.
- CoPs led by federal agencies. These CoPs supported pandemic responses by disseminating accurate guidance quickly and directly from the source. Their resources and connections enabled them to bring together key contributors to the response to present emerging guidance and address questions.

We refer to nonfederal CoPs as CoPs throughout the report unless otherwise specified. These CoPs brought together STLT public health agencies, nonfederal partners, and federal staff to translate COVID19 guidance into practice (Exhibit 1). By adapting the Knowledge to Action (K2A) Framework from the U.S. Centers for Disease Control and Prevention (CDC), we evaluated how CoPs facilitated moving guidance into actionable practices through tool creation, information dissemination, and enhanced collaboration. CoPs produced practical resources like checklists and protocols, shared data and updates, and connected various public health practitioners; in these ways, they enhanced the ability of STLT public health agencies to respond to the pandemic. They also promoted policy adoption by showcasing successful strategies and supported implementation with peer sharing and collaborative problem solving.

Key factors in the success of CoPs during the COVID-19 pandemic included a clear focus on issues important to members, strong connections between members, and a structure tailored to the group’s goals. Trustworthy facilitators, regular meeting schedules, and protective measures for confidentiality facilitated strong connections between members. Structures that could be tailored to the goals of the group included meeting frequency, the meeting format, and the number and variety of participants. For example, fewer participants facilitated more open communication, interaction, and learning, whereas more participants enabled broader information dissemination.

Among the nonfederal CoPs we interviewed, most engaged with federal agencies, often by inviting their staff to participate in calls to listen or share information. This coordination allowed federal agencies to clarify guidance and provide updates while they gained insight into STLT public health agencies’ needs. CoPs that received advance notice of guidance were better prepared to respond, whereas those that received updates simultaneously with or through the media faced challenges in preparing a response.

Having multiple information sources, including receiving guidance directly from federal sources and receiving other support through nonfederal CoPs, benefited CoP participants. Both CoP lead organizations and STLT participants noted that these channels served distinct purposes: federal agencies provided timely, accurate information, and CoPs offered tailored insights and lessons learned.

Exhibit 1 Nonfederal CoPs brought together STLT public health agencies, nonfederal partners, and federal staff to help move knowledge into action

CoPs moved knowledge to action through collaboration, sharing information, and creating resources. CoPs affected implementation of guidance, creating knowledge on best practices. Section 1.C has more detail on translating knowledge to action.

## Lessons learned and considerations

Our study identified several lessons learned and considerations for how federal agencies can fund, engage, and coordinate with nonfederal CoPs during future public health emergencies:

- Consider ways to solidify federal support for nonfederal CoPs through active participation and information sharing, when invited.
- Consider ways to formalize the role for partner organizations as CoP leads during public health emergencies.
- Consider additional avenues for federal agencies to identify and keep leaders of large, nonfederal CoPs informed about guidance development.
- Continue and consider expanding federal funding for nonfederal organizations to lead CoPs specifically for Tribal, local, and territorial communities.
- Consider ways the federal government, in collaboration with public health partners, can identify channels to disseminate useful tools and resources developed under nonfederal CoPs to make them widely available and to improve efficiency.
- Consider ways the federal government can support nonfederal CoPs in evaluating their efforts to evolve into the best structure for their specific needs.