# Acronyms

ASPE: Office of the Assistant Secretary for Planning and Evaluation
CDC: Centers for Disease Control and Prevention
CoP: community of practice
K2A: Knowledge to Action
STLT: state, Tribal, local, and territorial