# III Lessons Learned and Considerations

This study affirmed the crucial role of nonfederal CoPs in supporting STLT public health agencies with knowledge dissemination during the COVID-19 pandemic and underscored the benefits of federal collaboration with these CoPs. Additionally, the study highlighted the importance of maintaining designated spaces for public health staff and leaders at state, Tribal, local, and territorial levels to discuss their unique strategies, successes, challenges, and needs.

Although this study offered important insights on the role of nonfederal CoPs during the COVID-19 pandemic, it was exploratory in nature and included insights from only 21 interviewees. Therefore, it may not reflect the experience of all nonfederal CoP leaders, STLT public health agencies, and federal partners. We also recognize the important role that federally led CoPs played in disseminating information during the COVID-19 pandemic, though examining this role was outside the scope of this study.

In Exhibit 7, we summarize key lessons learned from our study. We also identify how these lessons might inform future considerations about how federal agencies can fund, engage, and coordinate with nonfederal CoPs during future public health emergencies.

Exhibit 7 Lessons learned about using CoPs to support STLT public health agencies during the COVID-19 pandemic and future considerations

Lessons learned | Future considerations
- STLT public health agencies benefited from having multiple information sources. They received guidance directly from federal sources and received tailored support through nonfederal CoPs. CoP lead organizations and STLT participants both noted that these channels served distinct purposes: federal agencies provided timely, accurate information, and CoPs offered more tailored insights and lessons learned. When federal agencies supported nonfederal CoPs through their active engagement, coordination improved. | - Consider ways to further solidify federal support for nonfederal CoPs through active participation and information sharing, when invited. Active federal support for nonfederal CoPs can enhance the translation of guidance into practice.
- Partner organizations, defined as those that receive federal grants or cooperative agreements to enhance the effectiveness of the public health system, offer an effective infrastructure for quickly engaging STLT public health agencies in CoPs during public health emergencies. Their established networks and resources facilitate rapid and efficient response coordination. | - Consider ways to formalize the role of partner organizations as CoP leads during public health emergencies. Federal agencies could incorporate enhanced CoP roles into grant funding for partner organizations and specify how these CoPs would coordinate with federal agencies during emergencies. One example is specifying how these CoPs could advise on guidance development and release.
- CoPs led by nonfederal organizations such as academic institutions and nonprofits were especially important in filling gaps before guidance was available. They also created forums for discussing sensitive topics and challenges that STLT public health agencies might not be comfortable discussing with federal agencies. Although federal agencies included some leaders of these CoPs in calls about messaging guidance, they did not include CoP leaders consistently. | - Consider additional avenues for federal agencies to identify and keep leaders of large, nonfederal CoPs informed about guidance development. Integrating these CoP leaders into federal channels for discussing guidance early in a public health emergency can help to ensure that messaging is consistent and federal guidance accurately disseminates through multiple channels.
- Nonfederal CoPs played a key role for Tribal, local, and territorial public health staff because federal CoPs didn’t consistently reach these organizations. Additionally, these CoPs helped nonfederal staff to tailor federal guidance to fit their contexts. These CoPs were also important avenues for the federal government to identify emerging needs for resources and additional support in these communities, as well as opportunities to improve guidance. | - Continue and consider expanding federal funding for nonfederal organizations to lead CoPs specifically for Tribal, local, and territorial communities. Providing consistent backing and resources to nonfederal organizations that lead CoPs in these communities can help ensure they have reliable avenues to discuss and tailor guidance to address their needs during public health emergencies.
- Nonfederal CoPs played a crucial role in translating guidance into practice. CoPs helped by generating and sharing products, disseminating information (and supporting information dissemination), engaging partners in the pandemic response, and facilitating peer sharing about successful strategies and approaches to overcome challenges. | - Consider ways the federal government, in collaboration with public health partners, can identify channels to disseminate useful tools and resources developed under CoPs to make them widely available and to improve efficiency. Federal agencies could partner to develop platforms to facilitate sharing tailored products and tools. A consistent communications channel would also support quicker and more efficient responses.
- Effective CoPs focused on problems of significance to their members, fostered strong connections between members, and had a structure tailored to the group’s goals. We found that variations in meeting frequency, federal involvement, and participant composition offered distinct advantages in different contexts. CoPs evolved over time to continue to meet participants’ needs. Relatively few CoPs in our sample conducted formal evaluations of their work, although several used informal approaches to identify what structures and supports were most helpful. | - Consider ways the federal government can support nonfederal CoPs in evaluating their efforts to evolve into the best structure for their specific needs. Providing resources and support for CoP leads to help them understand what’s working and not working in their specific context could enhance their ability to support public health agencies in responding to public health emergencies and advancing evidence-based policies and practices.