# II Key Findings

Following are the key findings that are the results from a literature review and interviews with CoP leaders, federal agencies, and STLT public health agency participants.

## A What is a community of practice?

CoPs are “groups of people who share a concern or a passion for something they do and learn how to do it better as they interact regularly” (Wenger-Trayner and Wenger-Trayner 2015). Cognitive anthropologists Jean Lave and Etienne Wenger coined the term “community of practice” when studying apprenticeships as a learning model (Lave and Wenger 1991). CoPs coalesce around topics of significance to individuals and through ongoing interaction foster the creation, exchange, and expansion of knowledge (James-McAlpine et al. 2023). CoPs have a domain or common interest, a community of relationships and connections fostered among members, and a practice of learning and shared resource development as members engage with one another (Exhibit 2).

Exhibit 2 Elements of communities of practice

Note: Adapted from https://www.communityofpractice.ca/background/what-is-a-community-of-practice/.

In the definition of communities of practice, the “shared concern for something” represents the domain. “Learning how to do it better” represents the practice, and “regular interactions” represents community.

## B What types of CoPs emerged to support STLT public health agencies during the COVID-19 pandemic?

We identified three types of CoPs, differentiated by their lead organization, that played significant roles in supporting STLT public health agencies during the COVID-19 pandemic (Exhibit 3). For each type, we discuss common reasons they were initiated, how they were funded, and their unique advantages and challenges in supporting STLT public health agencies.

Exhibit 3 Three types of CoPs played significant roles in supporting STLT public health agencies during the COVID-19 pandemic

Notes: Solid lines represent primary information sharing channels within each CoP type. Dotted lines indicate additional communication channels. Partner organizations are those that receive federal grants or cooperative agreements to enhance the effectiveness of the public health system. Other nonfederal organizations include academic institutions, philanthropic organizations, or nonprofits.

The main text paragraphs below describe each of the three types of CoPs, the entities involved in each type, and the flow of information in each type.

CoPs led by partner organizations (type 1). Partner organizations are organizations that receive federal grants or cooperative agreements to enhance the effectiveness of the public health system (Centers for Disease Control and Prevention [CDC] 2024). Partner organizations often used existing convenings to create COVID-19 CoPs. Several of these convenings were already aimed at distilling information and supporting peer learning opportunities for STLT public health staff. During the pandemic, these groups often layered additional activities on existing workgroups or convenings of their memberships to meet emerging needs. For example, they increased the frequency of meetings or introduced new opportunities or platforms for resource sharing and conversations with federal agencies. Several partner organizations are membership based (see the study terms text box). Their membership base allowed them to deploy resources quickly and efficiently. They used their deep understanding of STLT participants’ contexts to distill and tailor federal guidance. Through COVID-19 CoPs, partner organizations enhanced their understanding of members’ needs, helping them to determine how they or their federal partners could best provide support for their members’ pandemic response efforts. However, they often focused on their specific public health members, a focus that limited opportunities for broader collaboration with other essential partners in pandemic response.

Study terms

- Partner organizations are organizations that receive federal grants or cooperative agreements to enhance the effectiveness of the public health system. Examples include the National Association of County and City Health Officials, the Association of State and Territorial Health Officials, and the Council of State and Territorial Epidemiologists.
- Other types of nonfederal organizations include academic institutions, philanthropic organizations, and nonprofits.

CoPs led by other types of nonfederal organizations (type 2). Nonfederal organizations such as academic institutions, philanthropic organizations, or nonprofits led these CoPs. The CoPs operated independently and were funded from sources outside of the federal government, but occasionally engaged federal agencies. For example, one CoP described reaching out to testing experts at the federal government to present during meetings and answer questions. Early in the pandemic, when there was limited formal guidance and knowledge of COVID-19, organizations created some of these CoPs to fill specific gaps or achieve specific goals related to the COVID-19 response. These CoPs provided forums for discussing sensitive topics, such as challenges faced or concerns with the feasibility of implementing specific guidance in different political environments. In some cases, CoPs led by nonfederal organizations offered unique access to subject matter experts—such as researchers from academic institutions or communications specialists from emergency response organizations—based on the organization’s expertise and networks. However, nonfederal organizations often did not have existing STLT public health networks on which to draw. In some cases, this limited their ability to quickly find and gather CoP participants.

CoPs led by federal agencies (type 3). Federal agencies often initiated these CoPs to disseminate new guidance to a wide audience, answer questions from STLT public health agencies, and support STLT public health response. Some federal CoPs included calls hosted by CDC with state public health agency leaders in geographic divisions or regions. These CoPs helped distribute guidance directly from the source. Federally led CoPs could gather diverse federal staff important to specific response efforts to present emerging guidance or answer questions in CoP meetings. However, some interviewees perceived that these CoPs were top-down groups, focused on information delivery and at times too large to foster dialogue or discuss translation to specific contexts.

Through an environmental scan and scoping calls with key informants, we identified 32 COVID-19 STLT public health CoPs led by nonfederal organizations (types 1 and 2). In the rest of this report, we use “CoP” to refer to COVID-19 STLT public health CoPs led by nonfederal organizations, unless we specify otherwise. Appendix B presents the list of CoPs. These CoPs reflected a wide variety of topics and participants. Some CoPs formed to discuss implementing and adapting guidance for particular contexts. These included CoPs composed of Tribes implementing guidance as sovereign nations and of territories implementing guidance that was largely intended for U.S. states. Several CoPs focused their membership on STLT public health agency staff with specific roles in the pandemic response, such as epidemiologists, immunization program managers, or preparedness directors. Others included a variety of STLT public health agency staff. CoPs also focused on specific topics, such as responding to workplace outbreaks or preparing for and managing a medical surge. Many CoPs that supported STLT public health agencies are still active in some form today, underscoring their value. Their initial focus during the pandemic shifted, and these CoPs have adapted to address broader themes such as general preparedness, capacity building, and other emerging priorities.

In Exhibit 4, we list the characteristics of the CoPs we identified, including topic area, member type, activities performed by CoP leads to support CoP members, and type of lead organization. The CoPs we identified offer insight into the variety of CoPs available but likely do not represent a comprehensive accounting of all STLT public health CoPs led by nonfederal agencies during the COVID-19 pandemic.

Exhibit 4 Characteristics of nonfederal COVID-19 STLT public health CoPs

CoP characteristics | Percentage of CoPs with characteristic (N = 32)
CoP topic areas ^a^
Vaccination | 31 (n = 10)
Health equity in the COVID-19 response | 16 (n = 5)
General COVID-19 response best practices | 13 (n = 4)
Preparedness capacity | 13 (n = 4)
Prevention for a specific population (for example, K–12 schools, incarcerated individuals) | 13 (n = 4)
Contact tracing and exposure notification | 7 (n = 3)
Testing | 6 (n = 2)
Immunization information systems | 6 (n=2)
Laboratory | 6 (n = 2)
Clinical care and services | 3 (n = 1)
Therapeutics | 3 (n = 1)
CoP member types ^a^
Multiple | 37 (n = 12)
Specific categories of STLT staff (for example, epidemiologists, preparedness directors, immunization information system staff) | 16 (n = 5)
Tribal | 13 (n = 4)
Local | 9 (n = 3)
State | 9 (n = 3)
Territorial | 6 (n = 2)
CoP activities ^a^
Calls/meetings | 56 (n = 18)
Online community | 25 (n = 8)
Webinars | 9 (n = 3)
Workshops | 9 (n = 3)
Cohort trainings | 6 (n = 2)
Newsletters | 6 (n = 2)
Coaching | 6 (n = 2)
Roundtables | 3 (n = 1)
CoP lead organization
Partner organizations (type 1) | 59 (n = 19)
Other nonfederal organization (type 2) | 38 (n = 12)
Lead organization uncertain | 3 (n = 1)

a These numbers may not sum to 100 percent because some CoPs covered more than one of the topics or activities. In addition, because these findings are based on publicly available information and a limited number of interviews, they may underrepresent the true number of CoPs with these characteristics.

## C How did CoPs assist STLT public health agencies in translating knowledge and guidance into practice during the COVID-19 pandemic?

We applied and adapted the CDC’s Knowledge to Action (K2A) Framework to understand the role of CoPs in translating knowledge and guidance the federal government generated into practice at STLT public health agencies during the COVID-19 pandemic. The CDC’s three-phase K2A framework (see the K2A text box; Wilson et al. 2011) demonstrates how scientific knowledge and evidence-based policies, programs, and practices are moved into sustainable actions to improve public health. We focused on the translation phase of the framework to understand the experience of STLT public health agencies implementing federal guidance. Although CoPs likely supported scientific research around COVID-19 and the decision to translate that research into guidance at the federal level (research and translation phases)—as well as sustaining and improving COVID-19 response policies, programs, and practices over the long term (institutionalization phase)—these aspects of CoPs were outside the scope of our study.

Knowledge to Action Framework phases

1. Research: Generating scientific knowledge through discovery, including efficacy and effectiveness studies and evaluations
2. Translation: Implementing science-based knowledge, policies, and programs and generating practice-based evidence for further research
3. Institutionalization: Maintaining and further improving evidence-based programs, policies, and practices

CoPs played the role of “translation supporting structures,” defined in the K2A framework as structures that enhance organizational capacity to “plan, implement, evaluate, or sustain the translation phase of the intervention process” (CDC 2014). As translation supporting structures, CoPs supported planning and developing policies and practices in response to COVID-19 guidance, shared tools and resources to help STLT public health agencies with implementing policies and practices informed by the guidance, and offered peer learning opportunities to evaluate what was working. In Exhibit 5, we outline the elements of the translation phase in the K2A framework and how CoPs supported STLT public health agencies with these elements during the COVID-19 pandemic. Although we list CoP activities under a single element, some activities supported multiple aspects of translation.

Exhibit 5 How CoPs supported the translation phase of the K2A framework for STLT public health agencies during the COVID-19 pandemic

Note: We adapted the structure of this exhibit from the CDC's K2A framework (An Organizing Framework for Translation in Public Health: The Knowledge to Action Framework (https://stacks.cdc.gov/view/cdc/4186)) to include examples of CoP roles in translation identified in this study.

The main text paragraphs below describe how CoPs supported these activities: turning knowledge into products, disseminating guidance, engaging STLT public health agencies, influencing guidance adoption, and sharing promising practices.

CoPs supported the elements of the translation phase in the K2A framework in several ways:

- Creating programs, guides, toolkits, and other products (knowledge into products). During the COVID-19 pandemic, STLT public health agencies developed and shared products through CoPs that translated federal guidance into policies, programs, or interventions. For example, several CoP leaders mentioned that participants created and shared checklists and protocols for COVID-19 vaccine rollout that were informed by federal guidance on priority populations for vaccination.
- Sharing information and promising practices (dissemination). When federal agencies issued guidance, CoPs shared and discussed it with their members, often focusing on how it could be applied in CoP members’ communities. When formal federal guidance was still evolving, CoPs often shared emerging COVID-19 data or lessons learned from other response efforts to support STLT public health agencies with pandemic response strategies. Some CoPs also supported their members in disseminating guidance to their communities. For example, one CoP for Tribal communities created a messaging toolkit to communicate guidance about COVID-19 testing, masking, and vaccination in a way that was culturally relevant.
- Collaborating to influence policies and promising practices based on guidance (engagement). CoPs brought together different actors in the COVID-19 response and served as a central place for collaboration. CoPs that partnered closely with federal agencies often provided STLT public health agencies with a venue for bidirectional communication: they served as both a place to hear about emerging federal guidance and an opportunity for STLT public health agencies to share with federal agencies what was happening on the ground. A few participants noted that CoPs formed an important community for STLT public health agencies to advocate for new guidance, resources, or supports in the pandemic response. CoPs also presented an opportunity for different types or levels of STLT public health to connect with one another. For example, Tribal health agencies could connect with states to discuss approaches, and states could connect with local jurisdictions. As one CoP participant described, although state and local public health agencies do often have relationships, they don’t often have a venue for dialogue. The CoP provided a place where the states could learn more about what was working in the local context and gather feedback and information.
- Deciding to implement policies or promising practices based on guidance (decision to adopt). The guidance-based policies and practices peers shared in CoPs helped STLT public health agencies encourage the adoption of similar policies and practices in their settings. For example, one CoP leader described that participants often shared other CoP members’ successful strategies with their leadership to motivate similar action and work. They shared an example of a CoP participant who learned about another jurisdiction’s approach to school testing and convinced their own jurisdiction’s school leadership to replicate the strategy.
- Implementing policies or promising practices based on guidance (practice). Peers in CoPs often shared what was and was not working when implementing guidance-based policies and practices in their settings. This information helped CoP members to refine their approaches and address challenges. In some cases, CoP members also took collaborative action to implement a strategy. For example, one CoP with members in the same geographic area worked together to establish a distribution system for sharing vaccines when supplies were limited.

“I think it’s really helpful being in the same room with other jurisdictions.... It’s always nice to hear about what challenges other jurisdictions face, what unique or innovative programs they’ve implemented that could potentially be replicated.”

—CoP participant

CoPs also generated practice-based discoveries and evidence that helped to advance the COVID-19 response. Through the process of supporting STLT public health agencies with translation activities, CoPs generated knowledge and evidence about what was working in practice (called “practice-based discoveries” in the K2A framework). Sometimes CoPs shared this practice-based knowledge with federal agencies and the public health field more broadly to advance the COVID-19 response. For example, one CoP generated a step-by-step guide for implementing COVID-19 testing guidance in schools; the federal government then shared this resource more broadly.

## D What characteristics of CoPs were helpful to STLT public health agencies?

Several common themes emerged as key contributors to the success of CoPs in the literature. Our interviews with CoP leaders, federal agencies, and STLT public health agency staff confirmed these key themes and provided context on their applications for STLT public health CoPs. We describe each theme further below.

A clear focus on a shared problem or topic is critical to the success of CoPs generally (Bowman 2016; Edmonton Regional Learning Consortium n.d.; National Network of Public Health Institutes [NNPHI] 2020). The COVID-19 pandemic provided a clear and significant focus for STLT public health. Some CoPs adopted a singular focus within the pandemic and found doing so beneficial for achieving specific goals. In contrast, other CoPs addressed multiple topics. Often, these CoPs focused on whatever topics were of greatest interest to their members at that time; these interests evolved as the COVID-19 pandemic and response efforts changed.

“[The CoP] is also just a place to check up on people. COVID was really stressful. When we talk about workforce and the mental health of the public health workforce, [the CoP] was a place where you’re looking through the screen or you’re picking up the phone, [and] you knew that someone understood.”

—CoP leader

Strong connections between members and a safe environment are also important supports for sharing ideas and problem solving (Baker and Beames 2016; Bozarth 2013; NNPHI 2020; Wenger et al. 2011). The connections between members and the safe environment cultivated in COVID-19 CoPs helped STLT public health agency staff protect their mental health. Having a dedicated space for discussion with others facing similar challenges often helped participants feel supported during a difficult and stressful time. CoP leaders and participants described various approaches to ensure members felt connected with one another and comfortable sharing challenges in a safe environment:

- Using a trusted facilitator. This person was often someone who had preexisting relationships with participants and experience facilitating groups. In some CoPs, facilitators worked to build relationships with participants by meeting with them one on one outside of regular CoP calls, to learn more about their successes and challenges.
- Establishing a predictable cadence. Establishing a regular time for participants to meet helped to build connections between members. CoPs mentioned that members often felt more comfortable over time.
- Creating opportunities for participants to connect. Several CoP leads described incorporating icebreakers or opportunities for participants to socialize that helped to build connections and reinforce their shared goals.
- Protecting confidentiality. CoP leads tried to ensure participants were not concerned about other participants sharing their challenges with the media or others outside of the group. Specifically, they often opted not to record sessions or developed rules and norms stating that sensitive discussions wouldn’t be shared with people outside of the CoP.
- Dedicating time for federal involvement. Having federal partners actively participate and interact helped participants feel comfortable and valued. However, some CoP leads also purposefully reserved time or sessions without federal partners. They noted that STLT public health agency participants were often most comfortable sharing challenges among peers.

A structure tailored to the goals of the group is another component of successful CoPs (Baker and Beames 2016; Barbour et al. 2018; NNPHI 2020; Vital Strategies 2020). We anticipated identifying a specific way of organizing CoP meetings that was most helpful for STLT public health agencies during the COVID-19 pandemic. Instead, we found that variations in meeting frequency, structure, federal involvement, and participant composition each offered distinct advantages. In Exhibit 6, we outline different characteristics of nonfederal COVID-19 STLT public health CoPs and how each attribute contributed unique benefits.

Key insight: Variation in characteristics such as frequency and structure of meetings, federal influence, and variety and number of participants each had advantages depending on the individual CoP.

Exhibit 6 Advantages of variations in key structural characteristics of nonfederal CoPs

Characteristic | Advantages of less | Advantages of more
Meeting frequency | - Less frequent meetings enabled participants more time to focus on their jurisdiction’s pandemic response, potentially resulting in higher turnout.; - Less frequent but longer meetings allowed for intensive work on specific goals. | - More frequent meetings enabled participants to share newly released guidance and allowed participants to react and share operational or implementation approaches quickly for time-sensitive topics.
Meeting structure | - Less structured meetings allowed participants to shift focus to issues most pertinent to them, fostering organic peer learning. | - More structured meetings, with detailed agendas and presentations, ensured participants were up to date on certain information and helped with achieving specific goals.
Number of participants | - Fewer participants allowed for more open communication, interaction, and learning.; - Fewer participants allowed them to focus on specific topics and goals in more depth or to give feedback on emerging guidance. | - More participants allowed for more efficient and broad dissemination of information.
Federal influence | - Less federal influence in nonfederal CoPs contributed to participants’ perception that it was a safe space for sharing challenges or discussing politically sensitive topics. | - More federal influence in nonfederal CoPs enabled bidirectional communication.
Variety of participant roles | - Less variety in participant roles (for example, including participants that served in the same role across jurisdictions) fostered relationships through a common understanding of responsibilities and helped participants feel more comfortable sharing challenges. | - More variety in participant roles (for example, including participants that served in different aspects of the COVID-19 response) promoted cross-sector collaboration and resource sharing.

CoP leads generally used informal approaches to assess which structures were best suited to their members’ goals and to understand their CoP’s impact. CoP leads emphasized the importance of using different methods, such as participant surveys or one-on-one meetings with participants, to ensure the CoP remained responsive to participants’ needs. However, CoPs made few formal efforts to understand which structures were most effective, and only one CoP leader reported conducting a formal assessment of their CoP’s impact.

## E How did nonfederal CoPs coordinate with federal efforts and what was the experience for STLT participants receiving guidance and information from multiple channels?

Most nonfederal CoPs engaged with federal agencies in some form. Many nonfederal CoPs invited federal representatives to participate in calls as presenters or resources on an ad hoc basis. In some instances, particularly for CoPs led by partner organizations, federal agencies received standing invitations to listen to or participate in calls. These interactions sometimes occurred during dedicated portions of the agenda.

Coordination between nonfederal CoPs and federal agencies benefited both parties. As discussed in Section C, federal agency participation in nonfederal CoPs provided STLT participants with clarifications on guidance and updates on federal response efforts. When federal agencies participated in nonfederal CoPs, their involvement helped STLT participants build trust and confidence in the guidance by providing a direct connection to the source. At the same time, federal agencies gained valuable insights into the needs and experiences of STLT participants through the CoPs that could help them in their work.

“[STLT public health staff] needed not just the information, but they needed to have a sense of who the person was giving them the information and confidence that they could trust the person.”

—Federal agency participant

Nonfederal CoPs leads and STLT public health agencies participating in CoPs appreciated engaging with federal agencies on new guidance, either as sounding boards or as partners receiving advance notice. One nonfederal CoP lead said that they were included in a federal call on messaging guidance later in the pandemic, which they noted was helpful. However, some CoPs leads and STLT participants reported not being engaged early in the pandemic and as a result receiving updates on guidance simultaneously with, or through, the media. When this occurred, STLT public health agencies had less time to react to the guidance before receiving calls from the media and public asking for their response. STLT participants preferred when they were engaged more as collaborators in the following ways:

- Role in guidance development. Federal agencies involved some CoPs in developing their guidance. For example, they asked CoPs to survey all their members on specific issues or to identify smaller groups of members with highly relevant experience to serve as sounding boards. Federal agencies found using CoPs to identify relevant guidance users was valuable for understanding how STLT public health agencies might interpret or perceive proposed guidance before its broader release.
- Advance notice of guidance release. CoPs that received advance notice of guidance before it was public found this approach beneficial. STLT participants valued this early notice because it allowed them to prepare talking points, which helped show the public a united front between federal agencies and STLT public health.

In our limited sample of CoP participants, very few STLT public health staff reported significant unintended consequences or challenges of integrating information from various dissemination channels. Conversely, several STLT public health staff found having both federal and nonfederal information sources to be helpful and productive. STLT public health groups appreciated receiving guidance directly from federal agencies as well as through CoP lead organizations. Both CoP lead organizations and STLT participants noted that these channels served distinct purposes: federal agencies provided timely, accurate information, and CoPs generated more tailored insights and lessons learned.

Having multiple channels for receiving guidance proved beneficial for overcoming specific challenges including when guidance was insufficiently tailored or detailed, when there was turnover in key roles, and when frontline staff did not receive guidance directly. Nonfederal CoPs addressed these challenges by tailoring guidance, interpreting the guidance, and engaging frontline public health staff.

Key insight: Several CoP participants believed that receiving information and support from both federal and nonfederal sources was helpful and productive.

Nonfederal CoPs helped when guidance was not tailored to specific contexts. STLT participants did not always perceive the guidance provided by federal agencies as sufficiently tailored to their specific contexts or clear enough for them to confidently implement it. CoPs composed of Tribal and territorial public health groups—whose resources, infrastructure, and governance structures differ significantly from those of state and local public health groups—expressed this sentiment more strongly than did other participants.

Nonfederal CoPs helped when guidance was not focused on supporting implementation. CoPs sometimes perceived guidance as more science or research focused, with limited implementation details for practice settings. For example, an STLT public health participant in a CoP focused on case investigation and contact tracing reported that federal guidance did not cover topics such as technology systems for managing high caseloads or the staffing and training needs associated with case investigation and contact tracing.

Nonfederal CoPs helped when there was turnover in key roles. Turnover in key roles on both the federal and nonfederal side caused serious challenges for response efforts. Nonfederal CoPs served as a valuable tool for managing the challenges of turnover by providing a centralized repository of knowledge and connections. That is, when an individual came into a new role, they could enter the CoP and immediately build necessary connections.

Nonfederal CoPs helped fill a gap with direct federal engagement with frontline staff, including those in local health jurisdictions. For example, one CoP participant working on the COVID-19 response at a local health department said that federal agencies often shared guidance on COVID-19 with states and states sometimes did not share it with the local organizations or communicated it ineffectively. This participant described that nonfederal CoPs, particularly those with strong federal engagement, were an important way to stay informed on the latest guidance directly from the federal government. One federal agency also shared the importance of investing in frontline public health staff to ensure that there was adequate capacity and staff on the ground who had time to attend and learn from CoPs. This participant mentioned that if CoPs focus on the leadership level only, it limits their ability to translate guidance into practice.