# I Overview

The COVID-19 pandemic created an urgent need for state, Tribal, local, and territorial (STLT) public health agencies to translate knowledge and guidance into effective programs, policies, and practices. In this context, communities of practice (CoPs) emerged as crucial collaborative mechanisms by bringing together key partners to support STLT public health agencies. In addition to STLT public health agencies, these partners included federal agencies responsible for generating and disseminating guidance and nonfederal organizations— academic institutions, philanthropic groups, and partner organizations funded by the federal government—that played essential supporting roles.

Although CoPs existed prior to the pandemic, no study that we are aware of has examined their collective role in supporting STLT public health agencies including those implemented during the COVID-19 pandemic. To address this gap, we conducted a study of how CoPs supported STLT public health agencies during the COVID-19 pandemic (see study design text box). This study primarily focused on nonfederal CoPs to understand the extent of their alignment or coordination with federal efforts and to identify any unintended consequences or challenges faced by STLT public health staff when receiving guidance from multiple sources. We acknowledge that there were also federally led CoPs and CoPs for other types of organizations, but our study does not focus on them.

Study design

- An environmental scan to define CoPs and describe characteristics associated with their success
- Web searches and scoping calls with key informants to identify CoPs that facilitated disseminating, translating, and implementing the U.S. Department of Health and Human Services guidance to STLT public health agencies during COVID-19
- In-depth interviews with 21 people, including leaders and participants from 9 CoPs and federal agencies responsible for developing and disseminating COVID-19 federal guidance

Our study findings are informed by in-depth interviews with 21 people, including nonfederal CoP leaders, STLT public health agency staff who participated in nonfederal CoPs, and federal agency staff who supported nonfederal CoPs or understood the CoP landscape during the COVID-19 pandemic. We included CoP leaders and STLT public health staff that could speak to the state, Tribal, local, and territorial perspectives. We ensured our sample included the perspective of leaders and participants in CoPs not funded through federal cooperative agreements because of their potential unique challenges in aligning with federal initiatives and navigating guidance from multiple sources. More details about our methods and interview participants appear in Appendix A.

This report conveys the key findings of this study, organized around the following questions:

- What is a community of practice?
- What types of CoPs emerged to support STLT public health agencies during the COVID-19 pandemic?
- How did CoPs assist STLT public health agencies in translating knowledge and guidance into practice during the COVID-19 pandemic?
- What characteristics of CoPs were helpful to STLT public health agencies?
- How did nonfederal CoPs coordinate with federal efforts and what was the experience for STLT participants receiving guidance and information from multiple channels?

The report concludes with a summary of lessons learned and considerations about how federal agencies can fund, engage, and coordinate with nonfederal CoPs during future public health emergencies.