# Appendix B List of Nonfederal Communities of Practice Supporting STLT Public Health Agencies During the COVID-19 Pandemic

This table lists the 32 communities of practice that met inclusion criteria for our environmental scan (described in Appendix A).

Nonfederal led organization(s) | Communities of practice
Alaska Native Tribal Health Consortium | - Emergency Preparedness Support (https://www.anthc.org/covid-19-response/) – Regular meetings with Tribal health partners and clinical staff that involved sharing insights and interpreting new COVID-19 information.
American Immunization Registry Association^a^ | - Immunization Information System Best Practices Community of Practice (https://www.immregistries.org/iis-best-practices-community-of-practice) – Regular meetings for immunization information system (IIS) partners, including in public health agencies, to discuss IIS practices.; - Regional Workshops (https://www.immregistries.org/regional-workshops) – Regular meetings for IIS staff in geographic regions that support peer learning and provide national IIS updates and developments.
Association of Asian Pacific Community Health Organizations | - COVID-19 & Other Infectious Diseases Health Equity Response Network (CHERN) (https://www.immregistries.org/regional-workshops) – A series of monthly roundtables with health and community-based organizations serving Asian American, Native Hawaiian, and Pacific Islanders to discuss COVID-19 vaccination, clinical care, and other topics.
Association of Immunization Managers (AIM)^b^ | - iREACH – Racial and Ethnic Approaches to Community Health (https://www.immunizationmanagers.org/partnerships/reach-partnership/) – Regular calls, discussions, and an online forum with recipients of CDC’s REACH grants (including state and local health departments, Tribes, universities, and community-based organizations), focused on vaccine equity.
AIM, National Academy for State Health Policy (NASHP), and Academy Health^b^ | - Vaccine Access Cooperative (https://www.immunizationmanagers.org/vaccine-access-cooperative/) – Regular meetings and workgroups with state, territorial, and local public health agency teams to support COVID-19 vaccination in pediatric populations.
Association of Public Health Laboratories^b^ | - ColLABorate (https://collaborate.aphl.org/home) – Online communities and facilitated peer discussions between public health laboratory staff on topics such as wastewater surveillance and public health laboratory operations.; - COVID-19 National Public Health Laboratories Calls (https://learn.cste.org/calendar/cste-webinar/covid-19-response-membership-webinar-series) – Regular calls held in partnership with CDC for public health laboratory staff to discuss updated guidance related to COVID-19 laboratory testing.
Association of State and Territorial Health Officials (ASTHO)^a^ | - Public Health Preparedness Directors Peer Network (https://www.astho.org/members/peer-networks/) – Monthly meetings and an online community for state and territorial public health agency staff to share best practices for preparedness policy, including COVID-19 preparedness.; - State Health Official Member Calls – Weekly calls with ASTHO state health official members to discuss topics related to the COVID-19 pandemic and emerging guidance.
Council of State and Territorial Epidemiologists^a^ | - COVID-19 Response Membership Webinar Series (https://learn.cste.org/calendar/cste-webinar/covid-19-response-membership-webinar-series) – A webinar series for state and territorial epidemiologists to discuss COVID-19 topics such as vaccination, therapeutics, and exposure notification.
Duke Margolis Institute for Health Policy | - Supporting State Leaders in Addressing Challenges in COVID-19 Vaccine Distribution, Access, and Uptake (https://healthpolicy.duke.edu/projects/supporting-equitable-covid-19-vaccine-distribution-access-and-uptake) – A series of convenings for state public health leaders to discuss and address early challenges with COVID-19 vaccination.
Duke-Margolis Institute for Health Policy, National Governors Association Center for Best Practices,^a^ and NASHP | - Equity Learning Network (https://healthpolicy.duke.edu/projects/covid-19-health-equity-learning-network) – A series of conveninas with aovernor-appointed representatives, including state leaders in health equity, to discuss promising practices for improving equity in the COVID-19 response.
National Adult Immunization and Influenza Summit | - National Adult Immunization Coordinators’ Partnership (https://www.izsummitpartners.org/naicp/) – Quarterly calls to share strategies and best practices for increasing access to and uptake of adult vaccinations.
National Association of City and County Health Officials (NACCHO)^a^ | - Project Public Health Ready (https://www.naccho.org/programs/public-health-preparedness/pphr#cohort) – Annual cohort program including regular meetings to support local public health agencies with planning, responding, and recovering from public health emergencies.; - Roadmap to Ready (https://www.naccho.org/programs/public-health-preparedness/roadmap-to-ready) – Workshops and coaching for cohorts of new preparedness directors at local health departments.; - Workgroups (https://www.naccho.org/membership/advisory-groups) – Regular meetings with local public health agency members of NACCHO on various topics including preparedness, immunization, and infectious disease prevention.; - Virtual Communities (https://virtualcommunities.naccho.org/communities/allcommunities) – An online forum for discussing various topics including infection control and addressing health equity in the COVID-19 response.
National Congress of American Indians | - COVID-19 Task Force (https://archive.ncai.org/initiatives/partnerships-initiatives/resources-for-indian-country-coronavirus) – Group including Tribal public health organizations focused on supporting Tribal COVID-19 relief and recovery.
National Indian Health Board^a^ | - COVID-19 Tribal Resource Center (https://nihb.org/covid-19/) – A series of webinars and all-tribe calls to discuss the COVID-19 response.
National Network of Public Health Institutes^a^ | - COVID-19 Learning and Action Collaborative (https://nnphi.org/covid-19-action-and-learning-collaborative-archive/) – Video calls and online discussion groups for participants to share best practices and challenges in the public health response to COVID-19.
National Governor’s Association^a^ | - Vaccinate with Confidence Learning Lab (https://www.nga.org/projects/vaccine-with-confidence-learning-lab/) – Biweekly workshops with representatives from state public health agencies designed to support increasing COVID-19 vaccination.
Northwest Portland Area Indian Health Board^b^ | - Tribal COVID-19 Weekly Update Calls (https://www.npaihb.org/tribal-covid-19-weekly-update-calls/) – Regular calls with Northwest Tribal health leaders to share lessons learned, answer questions, and offer resources to support Tribes in the COVID-19 response.
Pacific Islands Health Officers Association^b^ | - COVID-19 Zoom Calls (https://www.pihoa.org/covid19/) – Weekly calls for all U.S.-affiliated Pacific Island health agencies to discuss the COVID-19 response.
Partners in Health | - U.S. Public Health Accompaniment Learning Collaborative (https://www.pih.org/article/pih-support-covid-19-response-across-us) – Regular learning sessions and an online community for public health agencies’ COVID-19 response, including contact tracing and health equity.
Resolve to Save Lives | - COVID Response Learning Community (https://preventepidemics.org/covid19/us-response/) – A community for public health teams and experts to share best practices in the COVID-19 response.
Rockefeller Foundation | - Pandemic Solutions Group (https://www.rockefellerfoundation.org/covid-19-national-pandemic-solutions-group/) – Biweekly conveninas of senior STLT public health officials that initially focused on sharing best practices for COVID-19 testing but later expanded to cover vaccination and other topics.; - State and Territory Alliance for Testing (https://www.rockefellerfoundation.org/covid-19-response/stat/) – An initiative that beaan with state governors banding together to purchase COVID-19 testing and later expanded to include the following:; – All-State Calls – Regular meetings for state public health officials to exchange best practices related to COVID-19.; – K–12 Action Network – Regular meetings with public health and education officials to address challenges with reopening schools.; – Vaccination Action Network – Regular meetings with public health officials, vaccination leaders, and COVID-19 task force directors to address challenges with COVID-19 vaccination.
Wayne State University | - Mitigating COVID-19 in Jail Settings Community of Practice (https://behaviorhealthjustice.wayne.edu/coronavirus/community-of-practice) – A monthly webinar series focused on strategies to mitigate COVID-19 in incarceration settings.

Note: We identified reciDients of cooDerative aareements as listed on CDC’s Cooperative Agreements, Grants, and Partnerships (https://www.cdc.gov/island-affairs/about/cooperative-agreements-grants-partnerships.html) page. We recognize that this list may not include other CDC or federal cooperative agreements and grants.

a Recipient of a CDC Strengthening Public Health Systems and Services Through National Partnerships to Improve Protect the Nation’s Health (https://www.cdc.gov/public-health-gateway/php/funding/capacity-building-assistance-ot18-1802.html?CDC_AAref_Val=https://www.cdc.gov/publichealthgateway/partnerships/capacity-building-assistance-OT18-1802.html).

b Recipient of other CDC cooperative agreement (APHL: https://www.cdc.gov/csels/dls/funding/announcements/oe20-2001/index.html; PIHOA: https://www.cdc.gov/publichealthgateway/partnerships/capacity-building-assistance-OT21-2101.html; NPAIHB: https://www.cdc.gov/tribal/cooperative-agreements/indian-country-services/nofo_overview.html).