# Appendix A Methods

We conducted an environmental scan and a series of in-depth qualitative interviews to answer the following research questions:

1. What were the nonfederal communities of practice (CoPs) that supported implementing federal guidance in state, Tribal, local, and territorial (STLT) public health practice during the COVID-19 pandemic?
2. Why were these CoPs initiated and what gaps did they fill? How were these funded?
3. Which CoP efforts were helpful to STLT public health agencies? How and why?
4. To what extent were the CoPs operated by nonfederal organizations aligned or coordinated with federal efforts?
5. What were any unintended consequences or challenges for STLT public health agencies to integrate knowledge arriving through a variety of dissemination channels?
6. What are lessons learned for future pandemics, for federal agency actions including collaborations with nonfederal CoPs? What are critical steps in the knowledge to action pathways that can be more efficient in the next pandemic?

## Environmental scan

To identify nonfederal CoPs supporting STLT public health agencies with the implementation of federal guidance during the COVID-19 pandemic (question 1 above), we conducted an environmental scan. We used a targeted search strategy to identify CoPs, including searching the websites of (1) key nonfederal organizations that provide technical assistance and support to STLT public health agencies, (2) organizations recommended by the Office of the Assistant Secretary for Planning and Evaluation, and (3) organizations such as Candid and Grantmakers in Health that compile tools and resources for foundations or philanthropies that may fund CoPs. We also conducted broad searches in Google and Google Scholar to look for additional COVID-19 STLT public health CoPs.

We searched websites (search strategy and list of websites described in Exhibit A.1 below) specifically for CoPs that met the following criteria:

- Based in the United States
- Led by a nonfederal organization
- Active during the COVID-19 public health emergency
- Intended for or substantially involving STLT public health agency members or other governmental public health staff
- Structured in a way that is suggestive of a community of practice (that is, involved in regular interaction and shared learning to develop member capabilities and to build and exchange knowledge)
- Focused on topics related to U.S. Department of Health and Human Services guidance on the COVID-19 pandemic, including but not limited to the following:
  – COVID-19 testing, treatment, vaccination, and therapeutics
  – COVID-19 case reporting and surveillance
  – COVID-19 pandemic response for specific populations or settings (for example, rural communities, K-– 12 schools, prisons/jails, individuals in nursing homes)
  – Promoting health equity in the COVID-19 response

We also identified any relevant publicly available evaluations on the CoPs identified.

Exhibit A.1 Websites included in search for CoPs and search strategy

Website | Date Accessed | Search Strategy
Association of State and Territorial Health Officials (https://www.astho.org/) | 1/30/2024 | - 1Reviewed site pages including peer network, COVID-19, and preparedness pages.; - Searched site for COVID-19 community of practice, COVID-19 convening, and COVID-19 learning network
Academy Health (https://academyhealth.org/) | 1/30/2024 | - Reviewed site pages including interest groups page.; - Searched site for COVID-19 community of practice and COVID-19 interest groups.
Alaska Native Tribal Health Consortium Epidemiology Center (https://epi.anthc.org/) | 2/1/2024 | - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Albuquerque Area Southwest Tribal Epidemiology Center (https://www.aastec.net/) | 1/31/2024 | - Reviewed COVID-19 page; - No website search bar available
American Immunization Registry Association (https://www.immregistries.org/) | 2/7/2024 | - Reviewed site pages including workgroups and events pages, pandemic, and outbreak response pages.; - Searched site for COVID-19, COVID-19 workgroup, COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Association of Asian Pacific Community Health Organizations (https://aapcho.org/) | 1/30/2024 | - Reviewed COVID-19 response page and links to networks on the page.
Association of Immunization Managers (https://www.immunizationmanagers.org/) | 1/30/2024 | - Reviewed site pages including partnership page.; - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Association of Public Health Laboratories (https://www.aphl.org/Pages/default.aspx) | 2/7/2024 | - Reviewed site pages including ColLABorate online communities, public health updates, and public health preparedness and response page.; - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Big Cities Health Coalition (https://www.bigcitieshealth.org/) | 1/29/2024 | - Reviewed site pages including the COVID-19 page.; - Searched site for COVID-19 community of practice COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
California Tribal Epidemiology Center (https://crihb.org/ctec/) | 1/31/2024 | - Reviewed site pages including public health updates page.; - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Candid (https://candid.org/) | 1/31/2024 | - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
CDC Foundation (https://www.cdcfoundation.org/) | 1/31/2024 | - Reviewed site pages including COVID-19 page.; - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Council of State and Territorial Epidemiologists (https://www.cste.org/?) | 1/31/2024 | - Reviewed site pages including COVID-19 response page.; - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
de Beaumont Foundation (https://debeaumont.org/) | 1/31/2024 | - Reviewed site pages including programs and past programs page.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Duke Margolis Center for Health Policy (https://healthpolicy.duke.edu/) | 1/31/2024 | - Reviewed site pages including COVID-19 Response page and list of projects (such as the Equity Learning Network) focused on the COVID-19 response.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Google | 2/8/2024 | - Searched US public health COVID-19 community of practice, COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Google Scholar | 2/8/2024 | - Searched US public health COVID-19 community of practice, COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Grantmakers In Health (https://www.gih.org/) | 1/31/2024 | - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Great Lakes Intertribal Epidemiology Center (https://www.glitc.org/programs/epidemiology-and-education/) | 1/31/2024 | - Reviewed site pages including COVID-19 response and public health updates page.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Great Plains Tribal Leaders’ Health Board (https://www.greatplainstribalhealth.org/) | 1/31/2024 | - Reviewed site pages including COVID-19 response and public health updates page.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Infectious Disease Society of America (https://www.idsociety.org/) | 1/31/2024 | - Reviewed site pages including COVID-19, professional development opportunities, and COVID-19 real time learning network pages.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Inter-Tribal Council of Arizona (https://itcaonline.com/) | 1/31/2024 | - Reviewed site pages including COVID-19 response, public health preparedness, public health updates, and vaccine page.; - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, COVID-19 learning network.
Johns Hopkins Bloomberg School of Public Health (https://publichealth.jhu.edu/) | 3/19/2024 | - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, COVID-19 learning network.
National Academy of Medicine (https://nam.edu/) | 3/19/2024 | - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, COVID-19 learning network.
National Academy of State Health Policy (https://nashp.org/) | 1/31/2024 | - Reviewed site pages including COVID-19 response page.; - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, COVID-19 learning network.
National Association of City and County Health Officials (https://www.naccho.org/) | 1/30/2024 | - Reviewed site pages including virtual communities page, education and events, preparedness, health equity, infectious disease, and membership pages.; - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, COVID-19 learning network
National Governor’s Association (https://www.nga.org/) | 1/31/2024 | - Reviewed site pages including COVID-19 projects page.; - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, COVID-19 learning network.
National Indian Health Board (https://www.nihb.org/) | 1/29/2024 | - Reviewed site pages including current and past projects.; - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, COVID-19 learning network.
National Network of Public Health Institutes (https://nnphi.org/) | 1/31/2024 | - Reviewed site pages including COVID-19, network engagement directory, and events page.; - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, COVID-19 learning network.
Navajo Epidemiology Center (https://nec.navajo-nsn.gov/about-us) | 1/31/2024 | - Reviewed site pages including infectious disease and public health updates page.; - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, COVID-19 learning network.
Northwest Portland Area Indian Health Board (https://www.npaihb.org/) | 1/31/2024 | - Reviewed site pages including projects, programs, COVID-19, and public health updates page.; - Searched site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, COVID-19 learning network.
Oklahoma Area Tribal Epidemiology Center (https://tribalepicenters.org/oklahoma-area-tribal-epidemiology-center/) | 1/31/2024 | - Reviewed site pages including COVID-19 response and public health updates page.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Pacific Islands Health Officers Association (https://www.pihoa.org/) | 1/31/2024 | - Reviewed site pages including COVID-19 page.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Partners in Health (https://www.pih.org/injusticehasacure?utm_source=bing&utm_medium=cpc&utm_term=partners%20in%20health&utm_content=text_covid&utm_campaign=DELVE_Fundraising&ms=pdbg&msclkid=dad0ae90dc89134f7615cb6ae3262ae9) | 1/31/2024 | - Reviewed site pages including COVID-19 response page, and how we work page.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Public Health Foundation (https://www.phf.org/Pages/default.aspx) | 1/31/2024 | - Reviewed site pages including focus areas, programs, and events pages.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Resolve to Save Lives (https://resolvetosavelives.org/) | 1/31/2024 | - Reviewed site pages including epidemic response and US COVID-19 response pages.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Robert Wood Johnson Foundation (https://www.rwjf.org/) | 1/31/2024 | - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Rockefeller Foundation (https://www.rockefellerfoundation.org/) | 1/30/2024 | - Reviewed site pages including STAT: State and Territory Alliance for Testing page.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Rocky Mountain Tribal Leaders Council (https://www.rmtlc.org/) | 2/1/2024 | - Reviewed site pages including COVID-19 response and other programs page.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
United South and Eastern Tribes Inc (https://www.usetinc.org/) | 2/1/2024 | - Reviewed COVID-19 response page and other programs page.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.
Urban Indian Health Institute (https://www.uihi.org/) | 2/1/2024 | - Reviewed COVID-19 response page and other programs page.; - Searched the site for COVID-19 community of practice, COVID-19 convening, COVID-19 learning collaborative, and COVID-19 learning network.

We compiled a list of CoPs that met our selection criteria. We shared this list with key informants that included representatives from federal agencies and nonfederal organizations who were familiar with the COVID-19 response and the breadth of CoPs available, to identify additional COVID-19 STLT public health CoPs and to refine our list. We identified 42 CoPs total and excluded 10 from our list because they did not meet inclusion criteria. The final 32 included CoPs appear in Appendix B below.

## In-depth interviews

To add depth and perspective to our understanding of CoPs, we conducted a series of in-depth qualitative interviews with nonfederal CoP leaders, STLT public health agency staff who participated in CoPs, and federal agency staff who participated in or partnered with COVID-19 STLT CoPs. To capture a diverse range of experiences, we used a purposive sampling approach to identify CoPs that represented distinct STLT public health staff populations and had a strong emphasis on peer learning through regular meetings. In total we were able to interview CoP leads from 9 of the 32 CoPs we identified through our environmental scan (Appendix B). These 9 CoPs could speak to the state, Tribal, local, and territorial perspectives and included a mix of type 1 and type 2 CoPs. We first reached out to leaders of these CoPs and used a snowball sampling approach to identify others with distinct roles in CoPs, such as participants and federal partners. We also used input from our early key informant interviews to identify federal leaders and other leaders of nonfederal CoPs who could provide perspective on the landscape of COVID-19 STLT CoPs.

We conducted 19 interviews with 21 participants (a few interviews included multiple participants), including nine CoP leads, six STLT participants in CoPs, and six representatives of federal agencies. We recorded and transcribed all interviews. The Health Media Lab Institutional Review Board approved the interview protocol and procedures (IRB #00001211, IORG #0000850).

## Analysis

A team of three researchers coded and analyzed interview transcripts to identify themes. Specifically, we identified key themes related to (1) how CoPs supported STLT public health agencies during COVID-19, particularly in translating knowledge into action; (2) barriers and facilitators to alignment or coordination between CoPs and federal efforts, and any challenges or unintended consequences encountered by STLT public health agencies when assimilating knowledge from various dissemination channels; and (3) lessons learned for future pandemics. One researcher coded each transcript, and another researcher reviewed the key themes identified. The team met regularly to discuss themes and interpretations of interview findings.