# 17 Bibliography

4YouandMe (no date) 4YouandMe. Available at: https://4youandme.org/our-studies/completed-studies (Accessed: 16 August 2023).
Abani, O. (2021) 'Convalescent plasma in patients admitted to hospital with COVID-19 (RECOVERY): a randomised controlled, open-label, platform trial', The Lancet, 397(10289), pp. 2049–2059.
Abani, O. (2022) 'Aspirin in patients admitted to hospital with COVID-19 (RECOVERY): a randomised, controlled, open-label, platform trial', The Lancet, 399(10320), pp. 143–151.
Adesoye, T., Katz, M.H.G. and Offodile, A.C., 2nd (2023) 'Meeting Trial Participants Where They Are: Decentralized Clinical Trials as a Patient-Centered Paradigm for Enhancing Accrual and Diversity in Surgical and Multidisciplinary Trials in Oncology', JCO oncology practice, 19(6), pp. 317–321.36821820
Adler, D. (2021) 'Inside Operation Warp Speed: A new model for industrial policy', American Affairs, 5(2). Available at: https://americanaffairsjournal.org/2021/05/inside-operation-warp-speed-a-new-model-for-industrial-policy/ (Accessed; 8 February 2024).
Agrawal, G. (2020) COVID-19 implications for life sciences R&D: Recovery and the next normal. McKinsey & Company. Available at: https://www.mckinsey.com/industries/life-sciences/our-insights/covid-19-implications-for-life-sciences-r-and-d-recovery-and-the-next-normal (Accessed: 12 August 2023).
Agrawal, G. (2021) 'No place like home? Stepping up the decentralization of clinical trials.' Available at: https://www.mckinsey.com/industries/life-sciences/our-insights/no-place-like-home-stepping-up-the-decentralization-of-clinical-trials (Accessed: 12 August 2023).
Aitken, M., Connelly, N. and Leamy, V. (2022) Lesson Learned from COVID-19 Vaccine Trials: A CRO perspective on accelerating clinical development. IQVIA Institute. Available at: https://www.iqvia.com/insights/the-iqvia-institute/reports/lesson-learned-from-covid-19-vaccine-trials (Accessed: 14 August 2023).
Alder, S. (2023) Is Zoom HIPAA Compliant?, HIPAA Journal. The HIPAA Journal. Available at: https://www.hipaajournal.com/zoom-hipaa-compliant/ (Accessed: 14 August 2023).
Ali, N. (2021) 'Remote monitoring using mobile phlebotomy and donor-derived cell-free dna in kidney transplant recipients during the covid-19 pandemic', American journal of transplantation: official journal of the American Society of Transplantation and the American Society of Transplant Surgeons, 21, pp. 566–567.
All of Us (2020) The All of Us Consent Process, All of Us Research Program / NIH. Available at: https://allofus.nih.gov/about/protocol/all-us-consent-process (Accessed: 12 August 2023).
Anderson, M. (2021) 'How the COVID-19 pandemic is changing clinical trial conduct and driving innovation in bioanalysis', 10.4155/bio-2021-0107, 13(15), pp. 1195–1203.34275327
Andrasik, M.P. (2021) 'Increasing Black, Indigenous and People of Color participation in clinical trials through community engagement and recruitment goal establishment', PloS one, 16(10), p. e0258858.34665829
Angus, D.C., Derde, L., (2020) 'Effect of Hydrocortisone on Mortality and Organ Support in Patients With Severe COVID-19: The REMAP-CAP COVID-19 Corticosteroid Domain Randomized Clinical Trial', JAMA: the journal of the American Medical Association, 324(13), pp. 1317–1329.32876697
Angus, D.C., Berry, S., (2020) 'The REMAP-CAP (Randomized Embedded Multifactorial Adaptive Platform for Community-acquired Pneumonia) Study. Rationale and Design', Annals of the American Thoracic Society, 17(7), pp. 879–891.32267771
Apostolaros, M. (2020) 'Legal, Regulatory, and Practical Issues to Consider When Adopting Decentralized Clinical Trials: Recommendations From the Clinical Trials Transformation Initiative', Therapeutic Innovation and Regulatory Science, 54(4), pp. 779–787.32557302
ATTACC Investigators (2021) 'Therapeutic Anticoagulation with Heparin in Noncritically Ill Patients with Covid-19', The New England journal of medicine, 385(9), pp. 790–802.34351721
Azar, A.M., II (2020) Determination that a Public Health Emergency Exists, HHSASPR Public Health Emergency. Office of the Assistant Secretary for Preparedness and Response. Available at: https://www.phe.gov/emergency/news/healthactions/phe/Pages/2019-nCoV.aspx (Accessed: 10 August 2023).
Baumann, B.C., MacArthur, K.M. and Michalski, J.M. (2020) 'The Importance of Temporary Telehealth Parity Laws to Improve Public Health During COVID-19 and Future Pandemics', International journal of radiation oncology, biology, physics, 108(2), pp. 362–363.32890513
Berard, A. (2021) 'Chloroquine and Hydroxychloroquine Use During Pregnancy and the Risk of Adverse Pregnancy Outcomes Using Real-World Evidence', Frontiers in pharmacology, 12, p. 722511.34408654
Boughey, J.C. (2021) 'Impact of the COVID-19 Pandemic on Cancer Clinical Trials', Annals of surgical oncology, 28(12), pp. 7311–7316.34236550
Bugin, K., Woodcock, J. (2021) 'Trends in COVID-19 therapeutic clinical trials', Nature Reviews Drug Discovery, 20(April), pp. 254–255.
Bustos, A. (2021) 'Machine Learning for Real-World Evidence Analysis of COVID-19 Pharmacotherapy', arXiv [cs.LG]. Available at: http://arxiv.org/abs/2107.10239.
Butler, C.C. (2021) 'Doxycycline for community treatment of suspected COVID-19 in people at high risk of adverse outcomes in the UK (PRINCIPLE): a randomised, controlled, open-label, adaptive platform trial', The Lancet. Respiratory medicine, 9(9), pp. 1010–1020.34329624
Butler, C.C. (2023) 'Molnupiravir plus usual care versus usual care alone as early treatment for adults with COVID-19 at increased risk of adverse outcomes (PANORAMIC): an open-label, platform-adaptive randomised controlled trial', The Lancet, 401(10373), pp. 281–293.
Castellon-Lopez, Y. (2023) 'A community-partnered approach for diversity in COVID-19 vaccine clinical trials', Journal of clinical and translational science, 7(1), p. e23.36714798
CDC (2023) CDC Museum COVID-19 Timeline, David J. Sencer CDC Museum; Exhibitions; Online Exhibitions. Available at: https://www.cdc.gov/museum/timeline/covid19.html#:~:text=January%2031%2C%202020&text=The%20Secretary%20of%20the%20Department,outbreak%20a%20public%20health%20emergency (Accessed: 23 July 2023).
CDC Vaccines (2023) How Vaccines are Developed and Approved for Use, CDC; Vaccines and Immunizations Home. Available at: https://www.cdc.gov/vaccines/basics/test-approve.html (Accessed: 22 July 2023).
College of American Pathologists (2020) Guidance for COVID-19 Testing for CAP-Accredited Laboratories, College of American Pathologists. Available at: https://www.cap.org/laboratory-improvement/news-and-updates/guidance-for-covid-19-testing-for-cap-accredited-laboratories (Accessed: 22 July 2023).
Compliance, H. (no date) 'HIPAA Compliance Datasheet’.
Connors, J.M. (2021) 'Effect of Antithrombotic Therapy on Clinical Outcomes in Outpatients With Clinically Stable Symptomatic COVID-19: The ACTIV-4B Randomized Clinical Trial', JAMA: the journal of the American Medical Association, 326(17), pp. 1703–1712.34633405
Cox, C. (2023) The end of the COVID-19 public health emergency: Details on health coverage and access, KFF. Available at: https://www.kff.org/policy-watch/the-end-of-the-covid-19-public-health-emergency-details-on-health-coverage-and-access/ (Accessed: 14 August 2023).
CTTI (2018) CTTI Recommendations: Decentralized Clinical Trials. CTTI Clinical Trials Transformation Initiative. Available at: https://ctti-clinicaltrials.org/wp-content/uploads/2021/06/CTTI_DCT_Recs.pdf.
Davis, M. (2023) 'Emergency powers and the pandemic: Reflecting on state legislative reforms and the future of public health response', Journal of emergency management (Weston, Mass.), 21(7 (Spec: Research and Applied Science: COVID-19 Pandemic Response)), pp. 19–35.37154443
De, B. (2021) 'Radiotherapy clinical trial enrollment during the COVID-19 pandemic', Acta oncologica, 60(3), pp. 312–315.33356801
Deb, P. (2022) 'Association of HLA gene polymorphism with susceptibility, severity, and mortality of COVID-19: A systematic review', Hladnikia, 99(4), pp. 281–312.
DiMe (2023) 'DE&I specific actions – digital medicine society (DiMe)'. Available at: https://dimesociety.org/access-resources/diversity-equity-inclusion/specific-actions/ (Accessed: 12 August 2023).
Dobriansky, J. and O'Farrell, P. (2018) Acquisition Innovation for Mission-Critical Force Readiness. Available at: https://acquisitioninnovation.darpa.mil/docs/Articles/Contract%20Management%20Dobriansky%20OTA.pdf (Accessed: 15 August 2023).
Dockendorf, M.F. (2021) 'Digitally Enabled, Patient-Centric Clinical Trials: Shifting the Drug Development Paradigm', Clinical and translational science, 14(2), pp. 445–459.33048475
Drury, R.E. and O'Connor, D. (2021) 'Symptom study app provides real-world data on COVID-19 vaccines', The Lancet infectious diseases, 21(7), pp. 890–891.33930321
Dyer, O. (2020) 'Covid-19: US states are not reporting vital data, says former CDC chief', BMJ, 370, p. m2993.32719009
Eichler, H.-G. (2022) 'Precision Reimbursement for Precision Medicine: Using Real-World Evidence to Evolve From Trial-and-Project to Track-and-Pay to Learn-and-Predict', Clinical pharmacology and therapeutics, 111(1), pp. 52–62.34716918
Evidera (2021) The Evidence Forum - Moving Evidence Forward. Available at: https://www.evidera.com/wp-content/uploads/2021/11/EFFall21-EvidenceForum-Web.pdf#page=4.
Federation of State Medical Boarders (no date) 'U.S. States and Territories Modifying Requirements for Telehealth in Response to COVID-19'. Available at: https://www.fsmb.org/siteassets/advocacy/pdf/states-waiving-licensure-requirements-for-telehealth-in-response-to-covid-19.pdf.
Fierce Healthcare (2023) 'CVS closing down clinical trials business after 2 years'. Available at: https://www.fiercehealthcare.com/retail/cvs-closing-down-clinical-trials-business-after-2-years (Accessed 28 August 2023).
Files, D.C. (2022) 'I-SPY COVID adaptive platform trial for COVID-19 acute respiratoryfailure: rationale, design and operations', BMJ open, 12(6), p. e060664.
Fitzsimmons, W.E., Idris, M.Y. and Pemu, P.E. (no date) 'Quantifying Clinical Trial Diversity of FDA Novel Drug Approvals', medRxiv: the preprint server for health sciences [Preprint], Available at: https://www.medrxiv.org/content/10.1101/2023.05.11.23289884v1.full.pdf.
Flores, S. (2021) 'Consequences of the COVID-19 Pandemic on Cancer Clinical Trials', Cancer medicine journal, 4(1), pp. 38–43.32601623
Florian, J., Forrest, F.C.A. and Randall, C.P. (2018) A new path forward for using decentralized clinical trials. Available at: https://dcricollab.dcri.duke.edu/sites/NIHKR/KR/GR-Slides-10-19-18.pdf (Accessed: 16 August 2023).
Freedberg, D.E. (2020) 'Famotidine Use Is Associated With Improved Clinical Outcomes in Hospitalized COVID-19 Patients: A Propensity Score Matched Retrospective Cohort Study', Gastroenterology, 159(3), pp. 1129–1131.e3.32446698
Galaitsi, S. E., Cegan, J. C., Volk, K., Joyner, M., Trump, B. D., & Linkov, I. (2021). 'The challenges of data usage for the United States' COVID-19 response' International Journal of Information Management, 59, 10.1016/j.ijinfomgt.2021.102352.
GAO (2021) COVID-19 Agencies Are Taking Steps to Improve Future Use of Defense Production Act Authorities. U.S. Government Accountability Office. Available at: https://www.gao.gov/assets/gao-22-105380.pdf.
Goossens, H. (2022) 'The European clinical research response to optimise treatment of patients with COVID-19: lessons learned, future perspective, and recommendations', The Lancet infectious diseases, 22(5), pp. e153–e158.34951954
Gordon, A.C. (2021) 'Interleukin-6 Receptor Antagonists in Critically Ill Patients with Covid-19', The New England journal of medicine, 384(16), pp. 1491–1502.33631065
Gottlieb, S. (2019) Breaking Down Barriers Between Clinical Trials and Clinical Care: Incorporating Real World Evidence into Regulatory Decision Making, U.S. Food and Drug Administration. Available at: https://www.fda.gov/news-events/speeches-fda-officials/breaking-down-barriers-between-clinical-trials-andclinical-care-incorporating-real-world-evidence (Accessed: 15 August 2023).
Grabenstein, J.D. (2022) 'Essential services: Quantifying the contributions of America's pharmacists in COVID-19 clinical interventions', Journal of the American Pharmacists Association: JAPhA, 62(6), pp. 1929–1945.e1.36202712
Greenough, M.C. (2022) 'The use of telecommunication and virtualization among ongoing and discontinued COVID-19 clinical trials: A cross-sectional analysis', Contemporary clinical trials, 114, p. 106681.35045363
Griffiths, G.O. (2021) 'AGILE: a seamless phase I/IIa platform for the rapid evaluation of candidates for COVID-19 treatment: an update to the structured summary of a study protocol for a randomised platform trial letter', Trials, 22(1), pp. 1–5.33397449
Harawa N.T., Amani B., Abotsi-Kowu C., Nwankwo E., Ford C.L. 'Using COVID-19 Surveillance Systems to Identify and Monitor Disparities: Best Practices and Recommendations'. Ethn Dis. 2022 Apr 21;32(2):151–164. doi: 10.18865/ed.32.2.151. PMID: 35497401; PMCID: PMC9037655.35497401
Hashem, H. (2020) 'Obstacles and Considerations Related to Clinical Trial Research During the COVID-19 Pandemic', Frontiers in Medicine, 7, p. 598038.33425945
Hatcher-Martin, J.M. (2020) 'Telemedicine in neurology', Neurology, 94(1), pp. 30–38.31801829
Health Care Compliance Association (2023) 'No More Boutique Studies': NIH Mulls 'Stopping Rules,' Other Changes to Improve Clinical Trials, JDSupra. Available at: https://www.jdsupra.com/legalnews/no-more-boutique-studies-nih-mulls-2480126/ (Accessed: 22 July 2023).
Heintz, H., Clouqueur, M. and Puopolo, J. (2021) 'Coping with Dementia Clinical Trial Interruption: Virtual Support Group for Participants and Study Partners', The American journal of geriatric psychiatry: official journal of the American Association for Geriatric Psychiatry, 29(4, Supplement), p. S113.
HHS (2020) 'Memorandum on Interim Guidance for Clinical Trial Activities Affected by the Novel Coronavirus'. Available at: https://ctep.cancer.gov/content/docs/Memorandum_on_Interim_Guidance_for_Clinical_Trial_Activities_Affected_by_the_Novel_Coronavirus-3-13-2020.pdf.
HHS HIPAA (2022) Guidance on How the HIPAA Rules Permit Covered Health Care Providers and Health Plans to Use Remote Communication Technologies for Audio-Only Telehealth, HHS.gov. US Department of Health and Human Services. Available at: https://www.hhs.gov/hipaa/for-professionals/privacy/guidance/hipaa-audio-telehealth/index.html (Accessed: 14 August 2023).
HHS Fact Sheet (2023) 'HHS Fact Sheet: Telehealth Flexibilities and Resources and the COVID-19 Public Health Emergency' Available at: https://www.hhs.gov/about/news/2023/05/10/hhs-fact-sheet-telehealth-flexibilities-resources-covid-19-public-health-emergency.html (Accessed 30 August 2023).
Higgins, A.M. (2023) Ľong-term (180-Day) Outcomes in Critically Ill Patients With COVID-19 in the REMAP-CAP Randomized Clinical Trial', JAMA: the journal of the American Medical Association, 329(1), pp. 39–51.36525245
Ho, J. (2017) 'Decentralized care for multidrug-resistant tuberculosis: a systematic review and meta-analysis', Bulletin of the World Health Organization, 95(8), pp. 584–593.28804170
Houhamdi, L. and Fournier, P.E. (2022) 'Smart apps for self-reporting clinical information', The Lancet, 399(10335), pp. 1575–1576.
Huang, D.T. (2021) 'Implementation of the Randomized Embedded Multifactorial Adaptive Platform for COVID-19 (REMAP-COVID) trial in a US health system—lessons learned and recommendations', Trials, 22(1), pp. 1–11.33397449
ICJME (no date) Clinical Trials, ICMJE; Recommendations; Browse; Publishing & Editorial Issues; Clinical Trials. Available at: https://www.icmje.org/recommendations/browse/publishing-and-editorial-issues/clinical-trial-registration.html (Accessed: 22 July 2023).
Ienca, M. and Vayena, E. (2020) 'On the responsible use of digital data to tackle the COVID-19 pandemic', Nature Medicine 2020 26:4, 26(4), pp. 463–464.
Inan, O.T. (2020) 'Digitizing clinical trials', npj Digital Medicine 2020 3:1, 3(1), pp. 1–7.
IQVIA (2023) 'Global Trends in R&D 2023 - IQVIA'. Available at: https://www.iqvia.com/insights/the-iqvia-institute/reports/global-trends-in-r-and-d-2023 (Accessed: 2023).
I-SPY COVID Consortium (2023) 'Report of the first seven agents in the I-SPY COVID trial: a phase 2, open label, adaptive platform randomised controlled trial', EClinicalMedicine, 58, p. 101889.36883141
Izmailova, E.S., Ellis, R. and Benko, C. (2020) 'Remote Monitoring in Clinical Trials During the COVID-19 Pandemic', Clinical and translational science, 13(5), pp. 838–841.32526077
Jackson, L.A. (2020) 'An mRNA Vaccine against SARS-CoV-2 - Preliminary Report', The New England journal of medicine, 383(20), pp. 1920–1931.32663912
Jethwa, H., Wong, R. and Abraham, S. (2021) 'Covid-19 vaccine trials: Ethnic diversity and immunogenicity', Vaccine, 39(27), pp. 3541–3543.34049734
Josan, K. (2021) 'Validation of a pandemic-proof, decentralized cardiovascular trial: scalable design produces rapid recruitment, high engagement and protocol adherence in DeTAP (Decentralized Trial in Afib Patients)', European heart journal, 42(Supplement_1), p. 3177.
Kaizer, A.M. (2023) 'Lopinavir/ritonavir for treatment of non-hospitalized patients with COVID-19: a randomized clinical trial', International journal of infectious diseases: IJID: official publication of the International Society for Infectious Diseases, 128, pp. 223–229.36581186
Khalil, L. (2022) 'Racial and Ethnic Diversity in SARS-CoV-2 Vaccine Clinical Trials Conducted in the United States', Vaccines, 10(2). Available at: 10.3390/vaccines10020290.
Kianersi, S. (2021) 'Use of research electronic data capture (REDCap) in a COVID-19 randomized controlled trial: a practical example', BMC medical research methodology, 21(1), pp. 1–9.33397292
Kohn, R. (2022) 'Comparing Smoking Cessation Interventions among Underserved Patients Referred for Lung Cancer Screening: A Pragmatic Trial Protocol', Annals of the American Thoracic Society, 19(2), pp. 303–314.34384042
Korley, F.K. (2021) 'Early Convalescent Plasma for High-Risk Outpatients with Covid-19', The New England journal of medicine, 385(21), pp. 1951–1960.34407339
Lackland, D.T. (2020) 'Impact of COVID-19 on Clinical Research and Inclusion of Diverse Populations', Ethnicity & disease, 30(3), pp. 429–432.32742146
Lasch, F. (2022) 'The Impact of COVID-19 on the Initiation of Clinical Trials in Europe and the United States', Clinical pharmacology and therapeutics, 111(5), p. 1093.35090044
LaVange, L. (2021) 'Accelerating COVID-19 Therapeutic Interventions and Vaccines (ACTIV): Designing Master Protocols for Evaluation of Candidate COVID-19 Therapeutics', Annals of internal medicine, 174(9), pp. 1293–1300.34181444
Leatherman, S.M. (2023) 'The impact of COVID-19 on a large pragmatic clinical trial embedded in primary care', Contemporary clinical trials, 129, p. 107179.37031794
Lee, E.Q. (2021) 'Report of National Brain Tumor Society roundtable workshop on innovating brain tumor clinical trials: building on lessons learned from COVID-19 experience', Neuro-oncology, 23(8), pp. 1252–1260.33822177
Licensing across state lines (no date). Available at: https://telehealth.hhs.gov/licensure/licensing-across-state-lines (Accessed: 15 August 2023).
Loche, A. (2020) COVID-19 and cell and gene therapy: How to keep innovation on track. McKinsey & Company. Available at: https://www.mckinsey.com/industries/life-sciences/our-insights/covid-19-and-cell-and-gene-therapy-how-to-keep-innovation-on-track (Accessed: 12 August 2023).
Lorch, U. (2012) 'The practical application of adaptive study design in early phase clinical trials: a retrospective analysis of time savings', European journal of clinical pharmacology, 68(5), pp. 543–551.22116461
Loucera, C. (2022) 'Real-world evidence with a retrospective cohort of 15,968 Andalusian COVID-19 hospitalized patients suggests 21 new effective treatments and one drug that increases death risk', bioRxiv. Available at: 10.1101/2022.08.14.22278751.
Loucks, T.L. (2021) 'Clinical research during the COVID-19 pandemic: The role of virtual visits and digital approaches', Journal of clinical and translational science, 5(1), p. e102.34192057
Lumpkin, M.M. (2022) 'Transparency practices at the FDA: A barrier to global health', Science, 377(6606), pp. 572–574.35926052
Lundgren, J.D. (2021) 'A Neutralizing Monoclonal Antibody for Hospitalized Patients with Covid-19', The New England journal of medicine, 384(10), pp. 905–914.33356051
Mahendraratnam N. (2022), 'Understanding Use of Real-World Data and Real-World Evidence to Support Regulatory Decisions on Medical Product Effectiveness.' Clinical Pharmacology and Therapeutics 111 (1): 150–54.33891318
Marra, C., (2021) 'Use of connected digital products in clinical research following the COVID-19 pandemic: a comprehensive analysis of clinical trials', BMJ open, 11(6), p. e047341.
McCarthy, M.W. (2023) 'Effect of Fluvoxamine vs Placebo on Time to Sustained Recovery in Outpatients With Mild to Moderate COVID-19: A Randomized Clinical Trial', JAMA: the journal of the American Medical Association, 329(4), pp. 296–305.36633838
McCreary, E.K. (2022) 'Launching a comparative effectiveness adaptive platform trial of monoclonal antibodies for COVID-19 in 21 days', Contemporary clinical trials, 113, p. 106652.34896293
McDermott, M.M. and Newman, A.B. (2021) 'Remote Research and Clinical Trial Integrity During and After the Coronavirus Pandemic', JAMA: the journal of the American Medical Association, 325(19), pp. 1935–1936.33885728
McLeod, C. (2023) 'Core protocol for the adaptive Platform Trial In COVID-19 Vaccine priming and BOOsting (PICOBOO)', Trials, 24(1), p. 202.36934272
McPhillips, D. (2023) The US still isn’t getting Covid-19 data right, CNN. Available at: https://www.cnn.com/2022/02/10/health/covid-data-problems/index.htm (Accessed: 11 August 2023).
Miller, K.L. and Miller Needleman, K.I. (2023) 'The effect of the COVID-19 pandemic on US Food and Drug Administration-funded clinical trials and natural history studies for rare diseases', Contemporary clinical trials, 129, p. 107198.37068589
Miseta, E. (2022) 'Tufts finds substantial net benefits to using decentralized trials'. Available at: https://www.clinicalleader.com/doc/tufts-finds-substantial-net-benefits-to-using-decentralized-trials-0001 (Accessed: 12 August 2023).
Mohamed Ibrahim, O. (2022) 'Shedding the light on Pharmacists' roles during COVID-19 global pandemic', Saudi pharmaceutical journal: SPJ: the official publication of the Saudi Pharmaceutical Society, 30(1), pp. 14–27.34961807
Moore, J. (2022) 'What role can decentralized trial designs play to improve rare disease studies?', Orphanet journal of rare diseases, 17(1), pp. 1–4.34983593
Naggie, S. (2022) 'Effect of Ivermectin vs Placebo on Time to Sustained Recovery in Outpatients With Mild to Moderate COVID-19: A Randomized Clinical Trial', JAMA: the journal of the American Medical Association, 328(16), pp. 1595–1603.36269852
Naggie, S. (2023) 'Effect of Higher-Dose Ivermectin for 6 Days vs Placebo on Time to Sustained Recovery in Outpatients With COVID-19: A Randomized Clinical Trial', JAMA: the journal of the American Medical Association, 329(11), pp. 888–897.36807465
NAS (2019) 'Virtual Clinical Trials: Challenges and Opportunities: Proceedings of a Workshop'. Available at: https://play.google.com/store/books/details?id=nie7DwAAQBAJ.
National Cancer Institute (2020) 'Updated Interim Guidance for Shipping Oral IND Agents to Clinical Trial Subjects during the COVID-19 Pandemic'. Available at: https://ctep.cancer.gov/content/docs/CTEP_Oral_IND_Agent_Shipments.pdf. Accessed August 28, 2020.
NIH Advisory (2023) Advisory Committee to the Director-June 2023 (Day 2). USA: NIH. Available at: https://videocast.nih.gov/watch=49764 (Accessed: 10 August 2023).
NIH Response (no date) NIH; NIH's Strategic Response, NIH COVD-19 Research. Available at: https://covid19.nih.gov/nih-strategic-response-covid-19 (Accessed: 10 August 2023).
NIH Therapeutics (2023) COVID-19 Therapeutics Prioritized for Testing in Clinical Trials, NIH » Research & Training » Medical Research Initiatives » ACTIV. Available at: https://www.nih.gov/research-training/medical-research-initiatives/activ/covid-19-therapeutics-prioritized-testing-clinical-trials#:~:text=The%20ACTIV%2D2%20protocol%20evaluated,of%20participants%20with%20undetectable%20virus. (Accessed: 10 August 2023).
Noonan, D. and Simmons, L.A. (2021) 'Navigating Nonessential Research Trials During COVID-19: The Push We Needed for Using Digital Technology to Increase Access for Rural Participants?', The Journal of rural health: official journal of the American Rural Health Association and the National Rural Health Care Association, 37(1), pp. 185–187.32282959
Ortigoza, M.B. (2022) 'Efficacy and Safety of COVID-19 Convalescent Plasma in Hospitalized Patients: A Randomized Clinical Trial', JAMA internal medicine, 182(2), pp. 115–126.34901997
Osborne, A. and Danheiser, S. (2023) Unlocking The Potential Of Decentralized Clinical Trials. Available at: https://www.clinicalleader.com/doc/unlocking-the-potential-of-decentralized-clinical-trials-0001 (Accessed: 14 August 2023).
Pallmann, P. (2018) 'Adaptive designs in clinical trials: why use them, and how to run and report them', BMC medicine, 16(1), p. 29.29490655
Pandit, J.A. (2022) 'Smartphone apps in the COVID-19 pandemic', Nature Biotechnology 2022 40:7, 40(7), pp. 1013–1022.
Pantasri, T. (2022) 'Expanded roles of community pharmacists in COVID-19: A scoping literature review', Journal of the American Pharmacists Association: JAPhA, 62(3), pp. 649–657.35120863
Parkins, K. (2021) 2022 forecast: decentralised trials to reach new heights with 28% jump, Clinical Trials Arena. Available at: https://www.clinicaltrialsarena.com/features/2022-forecast-decentralised-trials-to-reach-new-heights-with-28-jump/ (Accessed: 12 August 2023).
Park, J.J.H. (2022) 'Economic Evaluation of Cost and Time Required for a Platform Trial vs Conventional Trials', JAMA network open, 5(7), p. e2221140.35819785
Pepperrell, T. (2021) 'Making a COVID-19 vaccine that works for everyone: ensuring equity and inclusivity in clinical trials', Global health action, 14(1), p. 1892309.33627051
Pfizer (2021) Real-World Evidence Confirms High Effectiveness of Pfizer-BioNTech COVID-19 Vaccine and Profound Public Health Impact of Vaccination One Year After Pandemic Declared, Pfizer. Available at: https://www.pfizer.com/news/press-release/press-release-detail/real-world-evidence-confirms-high-effectiveness-pfizer (Accessed: 15 August 2023).
Pidala, J. (2013) 'Race/ethnicity affects the probability of finding an HLA-A, -B, -C and -DRB1 allele-matched unrelated donor and likelihood of subsequent transplant utilization', Bone marrow transplantation, 48(3), pp. 346–350.22863723
Pretzel, S. (2022) 'Willingness of Women with Endometriosis Planning to Undergo IVF to Participate in a Randomized Clinical Trial and the Effects of the COVID-19 Pandemic on Potential Participation', Reproductive sciences, 29(2), pp. 620–626.34363198
RECOVERY Collaborative Group (2020) 'Effect of Hydroxychloroquine in Hospitalized Patients with Covid-19', The New England journal of medicine, 383(21), pp. 2030–2040.33031652
RECOVERY Collaborative Group (2021) 'Dexamethasone in Hospitalized Patients with Covid-19', The New England journal of medicine, 384(8), pp. 693–704.32678530
Reis, G. (2022) 'Effect of early treatment with metformin on risk of emergency care and hospitalization among patients with COVID-19: The TOGETHER randomized platform clinical trial', Lancet regional health. Americas, 6, p. 100142.34927127
REMAP-CAP Study Investigators (2021) REMAP-CAP COVID-19 Publications, REMAP-CAP. Available at: https://www.remapcap.org/covid19publications?offset=1608692700642 (Accessed: 12 August 2023).
REMAP-CAP (no date) REMAP-CAP. Available at: https://www.remapcap.org/ (Accessed: 16 August 2023).
Rodriguez-Chavez, I.R. (2019) New trends in clinical trial designs: Decentralized clinical trials (DCTs). Available at: https://cersi.umd.edu/sites/cersi.umd.edu/files/DlS06-3-Chavez-v2.pdf (Accessed: 16 August 2023).
Roehr, B. (2011) 'Pfizer launches virtual clinical trial', BMJ, 342. Available at: 10.1136/BMJ.D3722.
Rogers, A. (2022) 'A systematic review of methods used to conduct decentralised clinical trials', British journal of clinical pharmacology, 88(6), pp. 2843–2862.34961991
Rose, G.L. (2022) 'Outcomes of Delay of Care After the Onset of COVID-19 for Patients Managing Multiple Chronic Conditions', Journal of the American Board of Family Medicine: JABFM, 35(6), pp. 1081–1091.36396416
Ruberg, S.J. (2023) 'Application of Bayesian approaches in drug development: starting a virtuous cycle', Nature reviews. Drug discovery, 22(3), pp. 235–250.
Rymer, J.A. (2022) 'One-Year Follow-Up of Vascular Intervention Trials Disrupted by the COVID-19 Pandemic: A Use-Case landscape', Cardiovascular revascularization medicine: including molecular interventions, 45, pp. 67–73.35953406
Sami, S.A. (2021) 'A comprehensive review on global contributions and recognition of pharmacy professionals amidst COVID-19 pandemic: moving from present to future', Future journal of pharmaceutical sciences, 7(1), p. 119.34150911
Saville, B.R. and Berry, S.M. (2016) 'Efficiencies of platform clinical trials: A vision of the future', Clinical trials, 13(3), pp. 358–366.26908536
Schofield, M. (2021) 'Regulatory and legislative issues on telehealth', Nutrition in clinical practice: official publication of the American Society for Parenteral and Enteral Nutrition, 36(4), pp. 729–738.34159667
Schwartz, A.L. (2023) 'Why Diverse Clinical Trial Participation Matters', The New England journal of medicine, 388(14), pp. 1252–1254.37017480
Sedhai, Y.R. (2021) 'Clinical trial enrollment at a rural satellite hospital during COVID-19 pandemic', Journal of clinical and translational science, 5(1), p. e136.34367680
Self, W.H. (2022) 'Neutralizing COVID-19 Convalescent Plasma in Adults Hospitalized With COVID-19: A Blinded, Randomized, Placebo-Controlled Trial', Chest, 162(5), pp. 982–994.35780813
Seltzer, J. (2022) 'The COVID-19 pandemic and cardiovascular issues in clinical trials: Practical and regulatory issues in remote monitoring of cardiac safety', American heart journal, 243, pp. 122–126.34555331
Shachar, C., Engel, J. and Elwyn, G. (2020) 'Implications for Telehealth in a Postpandemic Future: Regulatory and Privacy Issues', JAMA: the journal of the American Medical Association, 323(23), pp. 2375–2376.32421170
Shearn, C. and Krockow, E.M. (2023) 'Reasons for COVID-19 vaccine hesitancy in ethnic minority groups: A systematic review and thematic synthesis of initial attitudes in qualitative research', SSM. Qualitative research in health, 3, p. 100210.36573229
Shulkin David (no date) 'What Health Care Can Learn from Operation Warp Speed', Catalyst non-issue content, 2(1). Available at: 10.1056/CAT.21.0001.
Shuren, J. (2022) FDA's Center for Devices and Radiological Health's Continued Efforts to Return to Normal: Reopening for All Pre-Submissions, FDA; News & Events; FDA Newsroom; FDA Voices. Available at: https://www.fda.gov/news-events/fda-voices/fdas-center-devices-and-radiological-healths-continued-efforts-return-normal-reopening-all-pre (Accessed: 10 August 2023).
Sidky, H. (2023) 'Data quality considerations for evaluating COVID-19 treatments using real world data: learnings from the National COVID Cohort Collaborative (N3C)', BMC medical research methodology, 23(1), p. 46.36800930
Slaoui, M. and Hepburn, M. (2020) 'Developing Safe and Effective Covid Vaccines — Operation Warp Speed's Strategy and Approach', The New England journal of medicine, 383(18), pp. 1701–1703.32846056
Smith, Z., Botto, E. and Getz, K. (2022) 'Quantifying Diversity and Representation in Pivotal Trials Leading to Marketing Authorization in Europe', Therapeutic innovation & regulatory science, 56(5), pp. 795–804.35680722
Sommer, C. (2018) 'Building clinical trials around patients: Evaluation and comparison of decentralized and conventional site models in patients with low back pain', Contemporary Clinical Trials Communications, 11, pp. 120–126.30094387
Spinner, J. (2022) Lessons learned can help advance the future of DCTs: ObvioHealth, outsourcing-pharma.com. William Reed Ltd. Available at: https://www.outsourcing-pharma.com/Artide/2022/01/03/Lessons-learned-can-help-advance-the-future-of-DCTs-ObvioHealth (Accessed: 12 August 2023).
Spyropoulos, A.C. (2021) 'Efficacy and Safety of Therapeutic-Dose Heparin vs Standard Prophylactic or Intermediate-Dose Heparins for Thromboprophylaxis in High-risk Hospitalized Patients With COVID-19: The HEP-COVID Randomized Clinical Trial', JAMA internal medicine, 181(12), pp. 1612–1620.34617959
Stewart, J. (2022) 'Comparison of Racial, Ethnic, and Geographic Location Diversity of Participants Enrolled in Clinic-Based vs 2 Remote COVID-19 Clinical Trials', JAMA Network Open, 5(2), pp. e2148325–e2148325.35157053
Terhune, C. (2020) 'Special Report: How Korea trounced U.S. in race to test people for coronavirus', Reuters, 18 March. Available at: https://www.reuters.com/article/us-health-coronavirus-testing-specialrep/special-report-how-korea-trounced-u-s-in-race-to-test-people-for-coronavirus-idUSKBN2153BW.
The Good Science Project (2023) Creating A Clinical Trial Committee At The NIH, The Good Science Project. Available at: https://goodscienceproject.org/articles/creating-a-clinical-trial-committee-at-the-nih/ (Accessed: 22 July 2023).
Thio, C.L. (2001) 'Racial differences in HLA class II associations with hepatitis C virus outcomes', The Journal of infectious diseases, 184(1), pp. 16–21.11398104
Turner, J.R. (2020) 'New FDA Guidance on General Clinical Trial Conduct in the Era of COVID-19', Therapeutic innovation & regulatory science, 54(4), pp. 723–724.32557317
Unger, J.M., Xiao, H., (2021) 'Cancer Clinical Trial Participation at the 1-Year Anniversary of the Outbreak of the COVID-19 Pandemic', JAMA network open, 4(7), p. e2118433.34323986
Unger, J.M., Hershman, D.L., (2021) '"When Offered to Participate": A Systematic Review and Meta-Analysis of Patient Agreement to Participate in Cancer Clinical Trials', Journal of the National Cancer Institute, 113(3), pp. 244–257.33022716
U.S. FDA Adaptive (2020) 'Adaptive design clinical trials for drugs and biologies guidance for industry'. Available at: https://www.fda.gov/regulatory-information/search-fda-guidance-documents/adaptive-design-clinical-trials-drugs-and-biologics-guidance-industry (Accessed: 15 August 2023).
U.S. FDA Bayesian (2018) 'Guidance for the use of Bayesian statistics in medical device clinical trials'. Available at: https://www.fda.gov/regulatory-information/search-fda-guidance-documents/guidance-use-bayesian-statistics-medical-device-clinical-trials (Accessed: 14 August 2023).
U.S. FDA Conduct (2021) 'FDA Guidance on Conduct of Clinical Trials of Medical Products during the COVID-19 public health emergency', 11 April. Available at: https://www.fda.gov/regulatory-information/search-fda-guidance-documents/fda-guidance-conduct-clinical-trials-medical-products-during-covid-19-public-health-emergency (Accessed: 13 August 2023).
U.S. FDA DCT (2023) 'Decentralized Clinical Trials for Drugs, Biological Products, and devices'. Available at: https://www.fda.gov/regulatory-information/search-fda-guidance-documents/decentralized-clinical-trials-drugs-biological-products-and-devices (Accessed: 16 August 2023).
U.S. FDA DHT (2023) 'Digital Health Technologies (DHTs) for Drug Development’. Available at: https://www.fda.gov/science-research/science-and-research-special-topics/digital-health-technologies-dhts-drug-development (Accessed: 10 August 2023).
U.S. FDA Diversity (2020) 'Enhancing the Diversity of Clinical Trial Populations — Eligibility Criteria, Enrollment Practices, and Trial Designs Guidance for Industry'. Available at: https://www.fda.gov/media/127712/download (Accessed: 11 August 2023).
U.S. FDA Expedite (2020) Coronavirus (COVID-19) Update: FDA Issues New Policy to Help Expedite Availability of Diagnostics, FDA; News & Events; FDA Newsroom; Press Announcements. Available at: https://www.fda.gov/news-events/press-announcements/coronavirus-covid-19-update-fda-issues-new-policy-help-expedite-availability-diagnostics (Accessed: 22 July 2023).
U.S. FDA Industry (2020) 'COVID-19-Related Guidance Documents for Industry, FDA Staff, and Other Stakeholders (April 2020)'. Available at: https://web.archive.org/web/20200401165944/http:/www.fda.gov/emergency-preparedness-and-response/coronavirus-disease-2019-covid-19/covid-19-related-guidance-documents-industry-fda-staff-and-other-stakeholders (Accessed: 22 July 2023).
U.S. FDA Industry (2021) 'COVID-19-Related Guidance Documents for Industry, FDA Staff, and Other Stakeholders (December 2021)'. Available at: https://web.archive.Org/web/20211225022840/http:/www.fda.gov/emergency-preparedness-and-response/coronavirus-disease-2019-covid-19/covid-19-related-guidance-documents-industry-fda-staff-and-other-stakeholders (Accessed: 22 July 2023).
U.S. FDA Korea (2020) South Korea's Response to COVID-19. Available at: https://www.fda.gov/media/149334/download (Accessed: 10 August 2023).
U.S. FDA Role (2023) FDA's Role: ClinicalTrials.gov Information, FDA; Science & Research; Science and Research Special Topics; Clinical Trials and Fluman Subject Protection; FDA's Role: ClinicalTrials.gov Information. Available at: https://www.fda.gov/science-research/clinical-trials-and-human-subject-protection/fdas-role-clinicaltrialsgov-information (Accessed: 22 July 2023).
U.S. FDA Safety (2020) 'Ensuring the Safety of Patients in Clinical Trials Studying Investigational New Drugs to Prevent or Treat COVID-19'. Available at: https://www.fda.gov/drugs/coronavirus-covid-19-drugs/ensuring-safety-patients-clinical-trials-studying-investigational-new-drugs-prevent-or-treat-covid (Accessed: 30 August 2023).
U.S. FDA Staff (2023) 'COVID-19-Related Guidance Documents for Industry, FDA Staff, and Other Stakeholders. (May 2023)'. Available at: https://www.fda.gov/emergency-preparedness-and-response/coronavirus-disease-2019-covid-19/covid-19-related-guidance-documents-industry-fda-staff-and-other-stakeholders#archived (Accessed: 22 July 2023).
U.S. FDA Test (2022) COVID-19 Test Development and Review: FAQs on Testing for SARS-CoV-2, U.S. Food and Drug Administration. FDA. Available at: https://www.fda.gov/medical-devices/coronavirus-covid-19-and-medical-devices/covid-19-test-development-and-review-faqs-testing-sars-cov-2 (Accessed: 16 August 2023).
U.S. FDA - Trial Diversity (2022) 'Clinical Trial Diversity'. Available at: https://www.fda.gov/consumers/minority-health-and-health-equity/clinical-trial-diversity (Accessed: 16 August 2023).
Van Norman, G.A. (2021) 'Decentralized Clinical Trials: The Future of Medical Product Development?*', JACC: Basic to Translational Science, 6(4), pp. 384–387.33997523
Versavel, S. (2023) 'Diversity, equity, and inclusion in clinical trials: A practical guide from the perspective of a trial sponsor', Contemporary clinical trials, 126, p. 107092.36702295
Volpi, S.S. (2021) 'Using a mobile health app to improve patients' adherence to hypertension treatment: A non-randomized clinical trial', PeerJ, 9, p. e11491.34123593
Von Preyss-Friedman, S. (2022) 'Prediction of Deterioration from COVID-19 in Patients in Skilled Nursing Facilities Using Wearable Devices: A Feasibility Study', Journal of the American Medical Directors Association, 23(6), p. e12.
Walsh, E.E. (2020) 'Safety and Immunogenicity of Two RNA-Based Covid-19 Vaccine Candidates', The New England journal of medicine, 383(25), pp. 2439–2450.33053279
Waterhouse, D.M. (2020) 'Early Impact of COVID-19 on the Conduct of Oncology Clinical Trials and Long-Term Opportunities for Transformation: Findings From an American Society of Clinical Oncology Survey', JCO Oncology Practice, 16(7), pp. 417–421.32396491
Whanger, S. (2022) 'Novel Strategies to Increase COVID-19 Testing Among Underserved and Vulnerable Populations in West Virginia', American journal of public health, 112(S9), pp. S892–S895.36265093
Wilkinson, E. (2021) 'Dramatic drop in new cancer drug trials during the COVID-19 pandemic', The lancet oncology, 22(3), p. 305.33549163
Winch, G.M. (2021) 'Operation Warp Speed: Projects responding to the COVID-19 pandemic', Project Leadership and Society, 2, p. 100019.
Wired (2018) Scientists Hate the NIH's New Rules for Experimenting on Humans, Wired. Available at: https://www.wired.com/story/scientists-hate-the-nihs-new-rules-for-experimenting-on-humans/ (Accessed: 22 July 2023).
World Health Organization (2021) WHO Publishes new guidance to promote Strong, Efficient and Sustainable Regulatory Systems, WHO/News/WHO Publishes new guidance to promote Strong, Efficient and Sustainable Regulatory System. Available at: https://www.who.int/news/item/29-04-2021-who-publishes-new-guidance-to-promote-strong-efficient-and-sustainable-regulatory-systems (Accessed: 13 August 2023).
World Health Organization (2023) WHO COVID-19 Research Database, WHO COVID-19 Research Database. Available at: https://search.bvsalud.org/global-literature-on-novel-coronavirus-2019-ncov/?output=site&lang=en&from=101&sort=&format=summary&count=100&fb=&page=2&skfp=&index=&q=bayesian+clinical+trial (Accessed: 13 August 2023).
Xiao, H. (2023) 'Sex, Racial, and Ethnic Representation in COVID-19 Clinical Trials: A Systematic Review and Meta-analysis', JAMA internal medicine, 183(1), pp. 50–60.36469312
Yamal, J.-M. (2021) 'Successful conduct of an acute stroke clinical trial during COVID', PloS one, 16(1), p. e0243603.33449944
Younes, N. (2020) 'Challenges in Laboratory Diagnosis of the Novel Coronavirus SARS-CoV-2', Viruses, 12(6). Available at: 10.3390/v12060582.
Yu, L.-M. (2021) 'Inhaled budesonide for COVID-19 in people at high risk of complications in the community in the UK (PRINCIPLE): a randomised, controlled, open-label, adaptive platform trial', The Lancet, 398(10303), pp. 843–855.
Zoom (2021) 'HIPAA Compliance Datasheet'. https://explore.zoom.us/docs/doc/Zoom-hipaa.pdf (Accessed 1 February 2024).