# ACKNOWLEDGMENTS

- The expert interviewees
  Allison Kolbe, PhD, ASPE
  Trinidad Beleche, PhD, ASPE
  Deborah Porterfield, MD, MPH, ASPE
  Jessica White, MPP, ASPE
  Kathleen Miller, PhD, MS, ASPE
- FDA reviewers
  Marcelien Callenbach, MS (PhD candidate), Co-Bio Consulting
  Jacqueline Chen, MS (MD candidate), Co-Bio Consulting
  Mary (Kiwi) Florido, MS (PhD candidate), Co-Bio Consulting
  Jana Lipkova, PhD, Co-Bio Consulting
  Melissa Ouellet, MS, Co-Bio Consulting
  Caroline Zellmer, PhD, Co-Bio Consulting
  Donovan Griffin, BA, Mathematica
- Contract Officer’s Representative
  Marsha Clarke, PhD, ASPE