# 9 General operational considerations for clinical trials

As discussed in previous chapters, numerous operational innovations measurably mitigated COVID-19 impacts, accelerated urgent COVID-19 clinical development, or supported both. One expert recounted that accelerating COVID-19 vaccine trial initiation from (roughly) 300 to 100 days was only possible with meaningful changes to business practices, including pre-initiation consensus on collection tools and endpoints and highly streamlined reimbursement structures for clinical trial sites. This chapter discusses several specific operational considerations not included in the topics of the previous chapters.

Study planning: Several experts supported encouraging or even requiring pandemic contingency protocols for all clinical trials. These might include plans for protecting patients and personnel, such as increasing utilization of decentralized elements or DHTs, as well as plans for personnel diversion or exhaustion.

Study start-up: Launching a clinical trial involves coordinating several activities, including site selection, contracting and regulatory approval and alignment, and planning for participant recruitment. IQVIA reported that COVID-19 therapeutic trial start-up required only 1.5 months to initiate patient enrollment, an 83% reduction from the pre-pandemic 8.2-month benchmark (Aitken, Connelly and Leamy, 2022). This reduction in study start-up time has been attributed to features unique to the pandemic, including a pre-award site selection process that used models of participant density and diversity to identify sites with higher risk of severe disease, and dedicated start-up teams providing 24-hour virtual support for site document review to comply with country-specific regulations (Aitken, Connelly and Leamy, 2022). Of course, because COVID-19 was a common enough disease during the pandemic, potential participant identification was not a bottleneck for such trials. Notably, much of the evidence comes from trials associated with COVID-19 products themselves, which represent many of the most salient trials that were designed after the pandemic's onset and the release of FDA guidance documents. Other efficiencies highlighted by multiple interviewed experts came from streamlining study start-up processes across trials for COVID-19 products and other therapeutics. This involved implementing simplified protocols, such as using a central IRB process or a master protocol with amendments.

Another expert described streamlined institutional trial site contracting (e.g., via approaches including standardized rate cards, single IRBs, remote site monitoring) as helping to reduce trial timelines during the COVID-19 pandemic period. Traditional site contracting often necessitates lengthy and site-specific negotiations, as different centers have varying reimbursement rates for the same tasks (e.g., radiology scans, bloodwork, etc.). This issue was largely mitigated for COVID-19 products, however, through a "take-it-or-leave-it" strategy. Expert interviews highlighted how this simplified contracting helped start studies faster and felt that this type of standardization could drive further efficiencies beyond the COVID-19 pandemic. Of course, practical considerations need to be addressed (e.g., it may be desirable to geographically adjust standard reimbursement rates, as the Centers for Medicare & Medicaid Services does).

Trial recruitment: Patient recruitment for COVID-19 vaccine trials happened 52% faster and involved 80% larger and more diverse cohorts than previous vaccine trials, as reported by IQVIA (Aitken, Connelly and Leamy, 2022). During the pandemic, standard recruiting strategies were augmented by several innovative approaches. These included multichannel recruitment through social media advertising, emails, public awareness campaigns, referrals from local pharmacists, and involvement of ambassadors from local communities to target diverse subgroups (Sami et al., 2021; Aitken, Connelly and Leamy, 2022; Mohamed Ibrahim et al., 2022; Pantasri, 2022). For instance, the Pfizer/BioNTech vaccine trial (ClinicalTrials.gov Identifier: NCT04368728 (https://clinicaltrials.gov/ct2/show/NCT04368728)) recruited patients through social media and referrals from health care providers, while the ACTIV-2 Trial (ClinicalTrials.gov Identifier: NCT04518410 (https://clinicaltrials.gov/ct2/show/NCT04518410)) used targeted advertising to reach diverse populations, including adolescents and elderly people in the United States, European Union, and South Africa. The Healthy Lung trial (ClinicalTrials.gov Identifier: NCT04798664 (https://clinicaltrials.gov/ct2/show/NCT04798664)) (Kohn et al., 2022), launched in 2021, recruited most of its patients via text messaging. One researcher involved in leading the study underscored that this approach was particularly suitable for enrolling underrepresented and underserved patients. This sentiment was more broadly echoed by another expert on patients' diversity in clinical trials, who further emphasizing that many people are hesitant to answer calls from unfamiliar numbers, particularly those with 800 prefixes.

Database lock and analysis: This process involves gathering, certifying, refining, and analyzing all data that clinical trials will submit to regulatory authorities. COVID-19 therapeutic trials achieved a 95% faster database lock than standard trials (Aitken, Connelly and Leamy, 2022) by leveraging direct data entry and electronic data capture systems. This eliminated the need for manual data entry and consequent verification (Ienca and Vayena, 2020; Kianersi et al., 2021). In turn, this streamlined data collection and real-time data cleaning and, coupled with active involvement of all stakeholders, helped speed sponsors' decision making and further expedited the database lock process. The interviewed experts underscored that although these approaches were crucial during the pandemic, their benefits expand beyond emergency situations.

## Lessons Learned for general operational considerations

Having pandemic contingency plans in place for clinical trials would likely reduce disruption of clinical research in a future pandemic scenario.

Steps to streamline study start-up can greatly reduce time to develop new products during a pandemic. Although this primarily applies to a pandemic scenario, streamlined processes such as simplified protocols and simplified trial site contracting are lessons learned that could be applied to all clinical trials.

Innovative, non-traditional trial recruitment strategies, such as use of social media, text messaging, and community ambassadors, may speed enrollment and help recruit more diverse participants in clinical trials. These lessons learned can be applied outside of the pandemic to improve recruitment for all clinical trials.

More widespread adoption of direct data entry and electronic data capture systems for all types of trials will help expedite the database lock process and reduce clinical trial costs.