# 8 Regulatory trial oversight and evaluation

## Description of COVID-19 Impacts

The COVID-19 pandemic posed multiple challenges for the FDA and the clinical trialists for therapeutics and diagnostics who seek to meet regulatory requirements. Trials that were underway for non-COVID-19 products were interrupted with concomitant operational, statistical and compliance issues regarding how to continue without fully re-starting, and how to interpret the data from the interrupted protocols if they did so. New trials for COVID-19 products faced urgency to complete while also protecting participant and trialist safety as well as generating quality scientific results.

Based on the literature review and expert interviews, after an overview of pandemic regulatory activities, this section addresses:

- Trial and evidence generation influence
- Decision acceleration
- Regulatory coordination
- Regulatory resourcing

### Overview of pandemic regulatory activities

FDA, the Centers for Disease Control and Prevention (CDC), NIH, and other government agencies navigated the challenges of COVID-19 by issuing guidance documents and adapting processes while working to fulfill their responsibilities during the public health emergency.

FDA alone issued 84 COVID-19 related guidance documents from 2020 to 2022 (U.S. FDA Industry, 2021; U.S. FDA Staff, 2023), with 16 of those issued (as final documents) already in March 2020 (U.S. FDA Industry, 2020) just five to eight weeks after HHS declared a public health emergency on January 31, 2020 (Azar, 2020). Of those 84 guidance documents, at least 21 directly addressed human clinical trials (See Appendix D for a list). One covered veterinary product clinical trials, which are out of scope for this report. At least another 10 addressed medical device regulatory modifications due to the COVID-19 pandemic that would not require usual validation, which might have otherwise required clinical trial or trial-like activities. Those 10 plus at least another 18 guidance documents might have had indirect impacts on clinical trials through their effects on availability or variability of medical devices or clinical supply of drug products for clinical trials.

FDA was able to rapidly develop and release (final) guidance by using its Good Guidance Practices, under which the “...FDA will not seek public comment prior to implementing a guidance document if the agency determines that prior public participation is not feasible or appropriate" (U.S. FDA Staff, 2023). FDA occasionally updated its guidance documents, as exemplified by one of the most relevant examples for this report, which was originally issued in March 2020 and updated in August 2021: Conduct of Clinical Trials of Medical Products During the COVID-19 Public Health Emergency (Turner, 2020).

This early guidance document set the tone for much of the FDA clinical trial response by doing the following:

- Emphasizing that "ensuring the safety of trial participants is paramount"
- Encouraging sponsors "to evaluate alternative methods for safety assessments" from phone to virtual and from local alternative sites to home visits
- Altering monitoring schedules
- Promoting early consultation for proactive protocol and statistical analysis plan changes because of COVID-19 circumstances
- Considering remote monitoring of clinical sites

With respect to other opportunities to simplify operations and improve the efficiency of interactions with regulators, one expert highlighted the ongoing value of remote meetings. Before the COVID-19 pandemic, face-to-face meetings had been the norm with FDA regulators, but since the COVID-19 pandemic, even advisory committee meetings have been taking place over Zoom. The expert saw this as a pandemic-era change that was born out of necessity but welcomed the persistence of remote meetings.

Whether remote or not, and despite the desire by many product developers to continue such intensive interactions, current regulatory capacity constraints would need to be eliminated before broadly rolling out such practices according to interviewees familiar with the area.

Beyond issuing guidance documents, the speed of the regulatory response and flexibility was perhaps best illustrated by Moderna Therapeutics launching the first human vaccine trials on March 17, 2020, with Pfizer/BioNTech expanding its own Phase 3 COVID-19 vaccine trial to 44,000 patients six months later on September 14, 2020, and Johnson & Johnson expanding its vaccine trial to 60,000 patients one week after that on September 21, 2020. This rapid start-up and enrollment of trials for the Moderna and Pfizer/BioNTech vaccines permitted assessment of interim results in November 2020 that supported FDA's Emergency Use Authorizations and CDC Advisory Committee on Immunization Practices recommendations for use in adults in December 2020 (CDC, 2023).

NIH's strategic response also impacted the clinical trials it sponsored implicitly via the studies it chose to sponsor as well as the detailed requirements and approvals they required for trials during the COVID-19 pandemic period (NIH Response, no date). For example, the ACTIV public-private partnership employed seven adaptive master protocols to reduce administrative burdens and rapidly advance (or slow) candidate therapies for therapeutic approaches such as immune modulators or repurposed drugs, settings (inpatient or outpatient), and modalities (monoclonal antibodies), among others (NIH Therapeutics, 2023). The master protocols established common outcomes and statistical analyses among other elements, which regulated the quality of potential evidence generated. Some interviewees suggested that relying on academic networks might have resulted in more elaborate, complex, lengthy, and expensive trial arms than would have been the case had the same approach been executed by experienced commercial firms.

### Trial and evidence generation influence

FDA-issued specific trial guidance documents: Clearly and publicly stating trial recommendations, especially regarding patient follow-up and required vaccine efficacy thresholds, helped sponsors design and complete meaningful trials that met the requirements of regulatory review. The urgency for action amidst uncertainty and even fear might have provided a context for the broad welcome that the rapidly released documents received in the clinical development community. To its credit, the FDA was explicit in its desire and processes to update the guidance documents as evidence evolved and then did so, thoughtfully balancing improvement with the risks of excessive volatility. As one interviewee said:

"During a pandemic...Make sure that you have rules that are known to all parties, in black-and-white, so people can’t cheat. Large vaccine manufacturers knew what they needed to do. Those who didn’t do that had problems."

- Regulator

Unfortunately, no quantitative or qualitative research studies were found addressing the impact of these actions.

Diagnostic early development: Diagnostic testing posed challenges early in the COVID-19 pandemic. Lessons learned included the need to balance assay validation, manufacturing certification, and intended uses of the assays. Early diagnostic test assays were challenged in clinical trial validation and manufacturing, which had follow-on impacts on therapeutic and vaccine product development trials. An accurate and consistent assay to screen participants and ascertain their outcomes fundamentally enables the generation of valid clinical evidence for therapeutic and vaccine products.

Responding to critical COVID-19 test shortages early in the COVID-19 pandemic, on February 29, 2020, FDA issued a policy that allowed laboratories certified to perform high complexity tests consistent with requirements under FDA's Clinical Laboratory Improvement Amendments to begin using tests immediately upon completion of their validation while recommending the labs submit the validation data with an Emergency Use Authorization request within 15 days (College of American Pathologists, 2020; U.S. FDA Expedite, 2020). Although this expanded rapid public health monitoring capacity at a critical time, it also overwhelmed FDA's ability to review submissions (Shuren, 2022) and led to the use of what became recognized as highly variable COVID-19 diagnostics (Younes et al., 2020).

Diagnostic tests underlie the effective parallel clinical development of vaccines and therapeutics. Without reliable and available diagnostic tests, identifying and following patients to test an intervention's efficacy and safety is hindered or even infeasible.

"When every second counts, you cannot have ambiguity on the quality of these tests. [We] learned early on that one cannot develop a product without diagnosing whether the patient has the disease. You cannot start until you have a diagnostic you have confidence in...and we did not pay attention to having diagnostics that we could have faith in."

- Contract research organization executive

As a result, lessons have been learned for balancing timeliness and quality. FDA has expanded and clarified its policies for COVID-19 tests (U.S. FDA Test, 2022), which improve ongoing development for COVID-19 variants and provide a template for future pandemics. But FDA policy alone might not be sufficient. Avoiding similar outcomes in a future pandemic might require government specification and funding for diagnostic and assay development as well as direct government validation, such as the approaches South Korea used (U.S. FDA Korea, 2020; Terhune et al., 2020). An expert interviewee in the United States further endorsed aspects of South Korea's approach, such as using high-quality laboratory-grade samples when samples are rare at the beginning of a pandemic as well as establishing contracts ahead of time for developing and supplying diagnostics, including manufacturing capacity.

Vaccine development consultation: Through Operation Warp Speed, FDA and companies developing potential vaccines had frequent, sometimes daily, communications that, combined with the guidance documents on COVID-19 vaccine development, provided rapid detailed feedback to vaccine developers. In turn, vaccine developers could present potential clinical development improvements and COVID-19 mitigation actions for regulatory consideration before full implementation. Engaging the highest biopharmaceutical executives (chief executive officers, chief research and development officers) with corresponding FDA officials enabled all their organizations to be bold, refine ideas quickly, and implement rapidly when appropriate during the COVID-19 public health emergency.

Reduce use of under-powered or poorly designed trials: Up to 95% of COVID-19 therapeutic trials did not generate evidence of sufficient resolution to inform FDA regulatory decision making for approval or denial (Bugin and Woodcock, 2021). Some, including a former NIH deputy director well before the COVID-19 pandemic in 2017, have called for NIH processes to eliminate "SCTs (small crappy trials)" (Wired, 2018; The Good Science Project, 2023). NIH officials have expressed support for such new recommendations proposed by the Clinical Trials Stewardship Task Force to the NIH Advisory Committee to the Director on June 9, 2023, but they have not yet announced a process or time frame for their adoption (Health Care Compliance Association, 2023; NIH Advisory, 2023). FDA currently possesses power to pause or halt trials due to safety concerns (U.S. FDA Safety, 2020). Some interviewees suggested that, at least during public health emergencies, FDA could be granted and the assertively exercise authority for pandemic products to halt trials and trial initiations identified as uninformative to prevent disinformation that might emanate from such trials and because knowingly recruiting patients into uninformative trials is usually considered unethical.

Adaptive and platform trial reviews: Interviews suggested that the FDA initially struggled with reviewing the adaptive Bayesian interim and final analyses as well as the resultant seamless Phase 2/3 trials. Without additional resources and advanced tools, experts saw the labor-intensive FDA review of adaptive trials and master protocols as unsustainable outside of a public health emergency (see also Chapter 5, Platforms and statistical innovation in clinical trial design).

Essential data trials: Trials may collect multiple data elements that possess minimal value to the sponsor or FDA. The excess data might be collected out of an abundance of curiosity or caution, but the result is delay, expense, and perhaps barriers to trial expansion to broader community sites or use of home monitoring. One interviewee with direct experience said:

"FDA reviewers spend two weeks extra going through this excess data. It’s not just collecting it [that takes time], but also the agency review."

- Regulator

In accordance with best practices, it is particularly important during pandemics that trials be designed in consultation with FDA to collect the minimal essential outcome data required to assess the efficacy and safety of the candidate product for the benefit all stakeholders (from patients to sponsors and funders).

Risk-based development streamlining: Development plans generally were tailored according to the anticipated effect sizes (efficacy), safety profile, and regimen of the candidate product. This was especially true during the COVID-19 public health emergency, during which implicit or explicit value-of-information and risk-based design choices were emphasized to simplify and speed clinical development. Well-characterized product types such as monoclonal antibodies were occasionally allowed to perform truncated Phase 1 safety studies to rapidly initiate adaptive Phase 2/3 trials. Another example was how the difficulty in obtaining non-human primates for non-clinical safety studies during the COVID-19 pandemic led to significant discussion between sponsors and regulators on alternative strategies. All such opportunities to reduce or eliminate activities required intensive interaction among the sponsors and FDA to align risk-benefit views regarding which streamlining opportunities were appropriate for each product indication.

Bioequivalence/biosimilar studies: Generic small molecule manufacturers and biosimilar biologic products must demonstrate either bioequivalence or biosimilarity, which are often accomplished through targeted clinical trials. Experts suggested that during a pandemic, regulators could more vigorously exercise their existing authority—or be given expanded authority—to speed provision of reference product to potential generic and biosimilar manufacturers. Experts also suggested that FDA provide additional consultation to such firms to expedite authorization and therefore supply of urgently needed repurposed therapies.

### Decision acceleration

COVID-19 vaccine development was condensed to seven months for select vaccine development programs to achieve Emergency Use Authorization and less than three years to complete Phase 2/3 trials for a traditional approval. Before COVID-19, the average novel vaccine development program required 9.8 years, with the acceleration attributed to novel trial sequencing techniques such as seamless adaptive trials and elimination of "between-trial white space" (Aitken, Connelly and Leamy, 2022). The regulatory actions described above strongly contributed to those successful vaccine trial sequences and "white space" reductions.

### Regulatory coordination

Regulatory coordination successes and challenges emerged during the COVID-19 pandemic in inter- and intra-agency communications, data collection, and international regulatory coordination, particularly regarding reliance-based practices.

A notable success was the rapid communication to vaccine developers regarding the trial methods and desired vaccine performance thresholds (see above, Trial and evidence generation influence). This success required significant inter-agency coordination, which was occasionally difficult. For example, regulatory leaders noted disruptions to intragovernmental communications. The frequent turnover of members of the CDC COVID-19 response team (as frequently as every four to 12 weeks) proved to be a particular challenge for inter-agency collaboration and communication regarding COVID-19 therapeutic and diagnostic evidence requirements, which was eventually overcome. FDA and CDC built on this success and have further improved how they communicate to developers their combined vaccine requirements (CDC Vaccines, 2023).

Experts saw coordinated interaction among government agencies and private organizations as enablers of more efficient COVID-19 trials. The Operation Warp Speed task force was established to include multiple HHS and Department of Defense offices to support accelerated private sector clinical development activities, particularly in manufacturing (Shulkin David, no date; Slaoui and Hepburn, 2020; Winch et al., 2021). Operation Warp Speed created efficiencies by consolidating multiagency decision making into a single governing group and leveraging expedited government mechanisms from Other Transaction Agreements (Adler, 2021; Dobriansky and O'Farrell, 2018) and the Defense Production Act for contracting to FDA Emergency Use Authorizations for regulatory authorizations (GAO, 2021).

Improved data collection and then sharing among agencies could aid in future pandemics and ongoing development of products that impact public health. For example, the United Kingdom and Nordic countries, with more connected population health and medical reporting, could better understand

COVID-19 spread, recruit participants into trials, and monitor the impact of emergency authorized products. It required up to two years for CDC to gather immunization data for reasons ranging from inadequately computerized processes to lack of legal authority that required negotiating data use agreements with many states (Dyer, 2020; Davis et al., 2023; McPhillips, 2023). Even when collected, experts stated, and the literature supported, that the data could not provide timely, granular information regarding the characteristics of COVID-19 patient populations, such as biological sex, age, severity, and product usage (Galaitsi et al., 2021, Harawa et al., 2022). Such information could have informed everything from trial designs to post-authorization label refinement.

Internationally, FDA's interpretations of its confidentiality obligations to sponsors inhibited its ability to cooperate in global trial coordination, reviews, and reliance-based practices during the COVID-19 pandemic (World Health Organization, 2021; Lumpkin et al., 2022). External experts suggested that FDA possesses greater statutory freedom to share information than it currently exercises. A reexamination of those obligations might enable greater collaboration and data sharing in future crises to benefit people in America and elsewhere.

### Regulatory resourcing

Many of the activities described above required additional regulatory effort from FDA, CDC, NIH and other involved agencies and task forces. During the COVID-19 pandemic, regulatory experts stated that these additional resources often came from activities such as diverting staff from other work on non-COVID-19 products and existing staff working extraordinary hours (late into the night or early mornings, over weekends and holidays, and not taking paid time off). Although heroic, such resourcing is not sustainable.

"I am very worried as we go back to our daily activities—nightmare that COVID-19 was—that we don’t lose what we could learn from it going forward: How we could do clinical trials better, how we could be prepared to do them better in the intervening period, and how we could jump in more guickly if we have another pandemic."

- Regulator

Some process efficiencies, such as rolling reviews and team-based reviews, were also adopted and expanded in the mid to late periods of the public health emergency, but they did not eliminate the need for heroic and ultimately unsustainable working hours by many staff.

Resource constraints will require prioritizing which candidate products receive intensive regulatory attention and consultation, from early consultation through final review and release according to existing criteria and processes for programs including the pre-IND consultation program, the Breakthrough Therapy Designation, Priority Review, Accelerated Approval, and NIH-ACTIV platform trial selection. Without greatly expanded staffing and processes, unfettered FDA interactions cannot become part of the post-pandemic "new normal."

## Lessons Learned for regulatory trial oversight and evaluation

Experts suggested that benefiting from clinical trial innovations (platforms), statistical analyses (Bayesian), DCTs and DHTs, and novel preclinical approaches to mitigate non-human primate shortages requires significant communication and mutual education between FDA and sponsors. Building such connections and expertise benefits pandemic preparedness as well as non-pandemic drug development. In a pandemic, experts noted that frequent consultation among senior leaders of government and medical product (e.g., vaccine) developers aids alignment and rapid action and contributes to an increased likelihood of success.

Reducing data collection demands and regulators' data review demands through risk-based or value-of-information design to obtain the least information necessary to meet regulatory, payer, and patient/provider evidence needs can be an effective strategy to speed development in pandemic and non-pandemic contexts.

Rapid proactive guidance from regulators during an emergency minimizes disruption or complete loss of ongoing clinical trials as well as accelerated pandemic product development. Rapid issuance of clear clinical development guidance documents for each product type (e.g., vaccine, diagnostic device, or small-molecule or biologic therapeutic agent) galvanized researchers to pursue impactful product development, creatively and quickly. Similarly, expert developers recognized rapid publication of joint CDC and FDA vaccine evidence standards and effect thresholds, with subsequent enforcement (via additional legislative authority for public health emergencies if need be) of those standards by FDA—and by NIH and other federal agencies for the studies they fund—as critical to their success.

Robust validation for assays and diagnostics must be assured for all drug development programs, especially during a pandemic. Clinical diagnostics and assays for quantifying therapeutic effects are foundational to clinical trial recruitment, participant selection, randomization, and participant response measurement. Building assay development and validation capabilities via cross training of FDA staff to create regulatory surge capacity to review applications for infectious disease analyte specific reagents, laboratory-developed tests, and in-vitro diagnostics can help but may not alone resolve the issues under pandemic conditions. Establishing FDA assay validation centers, similar to South Korea's centralized approach, which is likely to be operated by contractors who guarantee capacity to do so under pandemic conditions, might further address the pandemic-specific assay and diagnostic challenges.

Heroic work can meet emergency needs but is not sustainable as a new normal as staff exhaustion and burn-out was observed by the experts. More rapid de-prioritization of non-pandemic activities with lower relative incremental net patient benefit, to provide adequate staffing for pandemic needs was also suggested for future pandemics. They also suggested using team-based regulatory reviews to spread workloads and increase process resilience.