# 7 Real-world evidence and the gap between clinical research and practice

FDA defines RWE as clinical evidence about the use and potential benefits or risks of a medical product derived from analysis of real-world data, such as data derived from DHTs or EHRs.

A 2023 study designed to provide a retrospective landscape analysis of how FDA used RWE in regulatory decisions before the COVID-19 pandemic found 34 instances of RWE submission between 1954 and 2020. The study found that 25% of cases were in the oncology setting, 18% in hematology, and 12% in neurology, and more than 50% of the products were intended for rare disease or pediatric populations (Mahendraratnam et al., 2022). These findings are consistent with RWE being used conservatively and primarily in situations in which evidence generation is otherwise difficult. Indeed, the authors conclude that "there is significant potential to further explore the role of [RWE] in regulatory effectiveness decision-making." Yet the authors' assert that the need remains for product regulators to "track, centralize, and make publicly available the scientific lessons learned from when [real-world data] is both accepted and rejected."

## Applications of RWE during the covid-19 pandemic

During the pandemic, researchers used RWE to accelerate the identification of various COVID-19 care improvements. For example, the Quebec Pregnancy Cohort was used to review the safety of hydroxychloroquine and chloroquine for pregnant women, an important population subset excluded from clinical trials (Bérard et al., 2021). Researchers mined EHRs to evaluate COVID-19 treatment outcomes (Sidky et al., 2023). In Spain, a retrospective cohort study sought repurposed drug candidates by analyzing COVID-19 patient survival after therapeutic use for other indications before COVID-19 hospitalization (Loucera et al., 2022). Due to fragmented medical data and lack of embedded research capabilities in clinical care, the United States relied substantially on research findings from other countries—the United Kingdom and Israel, among others (RECOVERY, 2020; Pfizer, 2021)—to identify effective clinical practices and candidate therapies early in the COVID-19 pandemic.

Despite the challenges, some U.S. efforts achieved notable successes. The National COVID Cohort Collaborative Data Enclave managed by the National Center for Advancing Translational Sciences at NIH established a harmonized EHR data set of patients tested for COVID-19 in 65 health care institutions. The data platform facilitated online query, visualization, and statistical analyses across large and diverse patient populations to identify patterns relevant to clinical COVID-19 challenges (Sidky et al., 2023). Machine learning techniques helped generate RWE regarding therapeutic efficacy in some settings (Bustos et al., 2021).

The literature review did not reveal any research that quantified the impact of RWE on improving care during the COVID-19 pandemic. Some studies mentioned the missed opportunity for leveraging RWE to enable continuous learning about treatments beyond emergency authorization (Eichler et al., 2022).

In interviews, experts primarily highlighted the value of real-world data and evidence as tools to augment, support, and build on evidence from clinical trials. Box 8 summarizes the types of real-world data used during the COVID-19 pandemic cited in the literature and by the interviewed experts. One pharmaceutical industry executive gave the example of health care in Israel, where early and rapid vaccine rollout enabled rapid learning that informed decision making in the country and internationally (Pfizer, 2021). Such a dynamic real-time approach to generating and using RWE in the lead-up to the authorization or approval of a medical product stands in contrast to more typical practices, in which RWE is generated for pharmacovigilance and confirmatory evidence (e.g., via legacy registries and phase 4 trials).

Box 8 Types of real-world data used in clinical trials during the COVID-19 pandemic

- EHR data and patient outcomes: Real-world control arms in platform adaptive trials
- DCTs and digital biomarkers: Participant generated endpoints that could be measured in real-world settings (e.g., participants wearing/using DHTs to collect real time data)
- Patient or disease registries used as a historical control data source or a recruitment mechanism, especially for rare diseases
- Patient-reported outcomes, including from at-home use cases, or through social media or patient advocacy groups to direct trial strategy

### Bringing clinical research and practice closer together: Opportunities and challenges

RWE can help unify clinical research and practice through iterative knowledge generation embedded in patient care. The COVID-19 pandemic spurred efforts such as REMAP-CAP, which integrated the clinical trial infrastructure with EHRs for near real-time prospective point-of-care randomized trials (Huang et al., 2021). Multiple experts spoke about the value and urgency of bringing clinical care and clinical practice closer together, citing the value of such approaches during the COVID-19 pandemic (see, e.g., Box 7 above on the RECOVERY trial) as well as the promise of driving greater efficiencies well beyond the COVID-19 public health emergency. One clinical trial expert emphasized the disconnect between clinical research and patient care, saying that the history of clinical trials and the Belmont Report itself have led practitioners to think about these as "separate worlds." Still, the expert pointed out, no other industry separates new learnings from existing models so completely as does medicine. An expert suggested that the COVID-19 pandemic pushed clinicians to appreciate the promise of a more unified approach to medical research and practice.

## Lessons Learned for RWE and the gap between clinical research and practice

Clinical trials during the COVID-19 pandemic demonstrated that RWE can rapidly inform clinical care and that real-world data can speed clinical trial recruiting. Yet fragmented health IT and medical information limited the ability of U.S. clinical trials to leverage real-world data in identifying potential trial participants, impeding patient recruitment, treatment, and monitoring. This then delayed RWE results to guide clinical practice in the use of existing therapeutics and prevented detailed product effect monitoring during emergency use with ongoing confirmatory trials. Reducing health data fragmentation while simultaneously allowing access by researchers could improve clinical trials during normal contexts and prove critical to rapid response during pandemics.