# 6 Participant diversity drivers and infrastructure

Many, including FDA, have emphasized the importance of including diverse communities in clinical research—both in studies investigating the treatment and prevention of COVID-19 and in clinical trials more broadly (U.S. FDA Diversity, 2020). Achieving participant diversity across age, race, ethnicity, geography, biological sex, gender, disability status, and other characteristics is an ongoing challenge in clinical research because of several structural barriers. Still, experts emphasized that diverse participation is necessary to gain community trust, promote fairness, and generate evidence on whether treatments have varying effects on different populations (Lackland et al., 2020; Jethwa, Wong and Abraham, 2021; Schwartz et al., 2023).

## Impact of COVID-19 trial disruptions and innovations on participant diversity

In interviews, experts said that clear recommendations from regulators on diversity requirements, such as those shared early in the COVID-19 pandemic, are necessary and will lead to more representative studies and generate benefits for a larger share of the population. Clinical trial participants should match the expected population of eligible patients for the condition and therapy. For example, although some trials, such as those for vaccines for COVID-19 should reflect the general adult population, others, such as those for therapies for sickle cell disease, should reflect the specific group of people who suffer from the target disease.

Research examining diversity in the set of clinical trials that investigated COVID-19 vaccines and therapeutics during the early years of the COVID-19 pandemic produced mixed results. Some studies reflect continuing diversity challenges: they have documented trials with racial and ethnic representation that are not reflective of the U.S. population and a lack of geographic heterogeneity (Pepperrell et al., 2021; Khalil et al., 2022; Xiao et al., 2023). For example, in a study of eight U.S. vaccine trials, the percentage of white participants ranged from 79% to 92% (U.S. FDA - Trial Diversity, 2022) - all of which represent a higher share of whites than in the U.S. population overall. For example, in a phase 1 vaccine trial of an mRNA vaccine conducted in 2020, 89% of the participants were white (Jackson et at., 2020). In addition, many trials did not publish demographic data, an omission that could indicate even greater disparities than those currently reported. Indeed, one study noted that "even when reported, 20% of studies did not follow the NIH's recommendation to report race and ethnicity as independent categories" (Pepperrell et al., 2021; Xiao et al., 2023). (See Appendix E Part II for a research feasibility demonstration for systematically considering clinical trial demographics.) As discussed below, however, the literature also identified several promising strategies to increase participant diversity identified and implemented during the COVID-19 pandemic.

### Approaches to improve participant diversity

Experts spoke about the need to improve communications more broadly. In particular, they emphasized that the standard legalistic participant consent process with its stilted communications materials and communication approaches could discourage underrepresented participants from enrolling. One expert said that typical communication and consent approaches may be particularly intimidating for underrepresented populations and in the context of severe illness (e.g., oncology trials). Because of common misunderstandings, participants might not be aware that in many clinical trials—and certainly in settings such as oncology trials—that there is no "sugar pill." Rather, by participating in clinical trials, participants will be guaranteed the standard of care—a notion that the expert implied was not widely known. Quantitative research regarding cancer trials suggests that trialists do not offer participation to underrepresented populations as frequently, but, when given the opportunity, those populations participate at similar rates to other groups (Unger, Hershman, et al., 2021).

Research has also suggested that efforts to improve diversity can succeed. Existing barriers remained a challenge for clinical trial enrollment of diverse populations after COVID-19 began. Such barriers include proximity to clinical trial site location, the vernacular and approaches used to recruit participants, and suitable compensation. One expert shared that although trialists can discuss diversity at length, emphasizing feasibility of participation might be the most important factor.

"Everything we can do to maximize the opportunity to participate for people regardless of their personal and demographic circumstances will be a win for the pace of approval, the internal validity, the diversity, generalizability, upholding of basic principles of fairness, the ability to rebuild considerable degradations in trust of the health care system."

- Medical ethicist and epidemiologist

Consequently, explicit efforts to increase diversity in trial enrollment during COVID-19 using DHTs and decentralized approaches might have contributed to better diversity enrollment outcomes. DCTs and DHTs extend the reach of clinical trials into the community or even individual homes. This, in turn, can help include populations that otherwise might not participate because of geographic, mobility, financial, or other barriers. One study showed that some remote trials during the COVID-19 pandemic were more geographically diverse (Stewart et al., 2022). These more representative trials often involved strategies to increase and evaluate diversity throughout the multiple phases of the clinical research process, including community engagement; identification and removal of financial barriers to participation; creation of culturally tailored recruitment materials, which resulted in more racial and ethnic diversity among participants in COVID-19 vaccine trials; and use of virtual visits, remote technology, and local laboratories to reach more diverse communities and limit the financial and time burden on patients (Andrasik et al., 2021; Stewart et al., 2022; Castellon-Lopez et al., 2023; Versavel et al., 2023). Researchers and interviewed experts have emphasized that the best communication and outreach approach will vary by the targeted (sub-)population. For instance, the RADx^®^ Underserved Populations group found that barber shops and hair salons were highly influential in encouraging other types of COVID-19-related health decisions (Whanger et al., 2022).

Heightened efforts to increase diversity in COVID-19 research succeeded in recruiting more diverse cohorts than ever before. One study showed that COVID-19 vaccine trials launched later in the COVID-19 pandemic enrolled Black, Indigenous, people of color participants at a faster rate because of existing networks and relationships, underscoring the value of maintaining community relationships (Andrasik et al., 2021). One expert noted that in a COVID-19 vaccine trial, Moderna briefly paused enrollment to satisfy the diversity metrics established by FDA (U.S. FDA - Trial Diversity, 2022). Another expert mentioned that their employer, a large pharmaceutical company, was shifting its strategy to partner with fewer but more varied study sites in the hope of improving trial efficiency and trial participant diversity. Another trialist shared that they had eight weeks to recruit 40,000 participants, and, given such a short time frame, there is very little "course correction" that can be performed. The trialist said that, by recruiting through registries, they were able to understand the characteristics of the potential participant population (including comorbidities) and estimate the feasibility of achieving participant diversity targets. Leveraging patient registries also facilitated direct-to-patient interactions. The same trialist said that the approach has broad applicability beyond pandemics, whenever registries are available.

In contrast, regarding COVID-19 diagnostic evaluation, the environmental scan found that diversity did not appear to be a key priority in their characterization and performance validation (Lackland et al., 2020; Jethwa, Wong and Abraham, 2021; Schwartz et al., 2023).

### The connection between technology and diversity

As described above, decentralized approaches to clinical trials and the technologies that support these approaches can increase participant diversity in trials. Yet, some studies warn that DHTs might widen clinical research disparities in practice because of the "digital divide" that disadvantaged communities often experience (Loucks et al., 2021). One trialist countered that using text messaging in their clinical trials aided enrollment and trial execution for underrepresented populations, as most people have cell phones. Context-specific research, technical and informational support, and monitoring are likely necessary to ensure that digital strategies achieve their diversity aims for participants of clinical research.

A digital technology expert said that trialists must engage community representatives when designing clinical trials, adding that if trial leaders are not certain how to engage diverse communities, then the wrong people are in leadership positions. Another trialist discussed the unique challenges and opportunities associated with diverse recruitment, saying that the clinical trial community needs to think about new mechanisms for community engagement and creatively "going the last mile." This expert said that there is a Walmart within 10 miles of 90% of the entire U.S. population, a reach that no health system can match, which emphasizes the potential value of partnerships with retail pharmacies and similar retailers. Although the expert recognized that engaging all communities will demand additional financial resources or entirely novel approaches to recruiting for and conducting clinical trials, the results will be better and maximally relevant. Furthermore, reluctance to adopt approaches that are known to improve recruiting and communications with minority audiences, such as text messaging and community outreach, will likely have a negative impact on a trial's ability to achieve its diversity goals. Several experts cited the value of using the Digital Medicine Society's tools and playbooks for trial diversity inclusion going forward (DiMe, 2023).

One expert gave the example of successful remote collection of bio-samples and patient-reported outcomes. The trial in question evaluated healthy lungs and provided participants with an option for mobile bio-sample collection. Although doing so was costlier, the expert emphasized that the costs made trial participation and participant retention easier, thereby supporting greater diversity. Further, once the COVID-19 pandemic occurred, patients avoided the clinic, and 67% of collection happened through mobile units.

Another expert cited the acceleration of web- or EHR-based tools to collect patient-reported outcomes with clinically and economically relevant measures. Indeed, experts spoke about the value of incorporating clinical trial recruitment technologies into the EHR more broadly—an approach with multiple possible advantages, one of which is establishing a constant pool of representative and diverse patients. (Other advantages of EHR-based recruitment are discussed above in the context of platform trials; see Chapter 5, Platforms and statistical innovation in clinical trial design.)

## Lessons Learned for increasing participant diversity in clinical trials

The COVID-19 impacts on participant diversity cited above appear to apply equally well to pandemic and normal contexts across all products. Explicitly including diversity recruitment activities into clinical trial plans is the core and consistent lesson emphasized. How best to include diversity recruitment plans, which activities to select, and how to fund them remain unresolved. Planning for a diverse trial might also include employing registries and addressing barriers to participation, such as by providing financial compensation.

A second lesson emphasized by nearly all the literature and experts is that recruiting diverse participants requires "meeting them where they are" geographically and culturally (for example, at formal or informal community gathering locations—or simply in their own homes, workplaces, and other frequently visited locations—and through engaging trusted community leaders, whether secular, religious, tribal, or advocacy-oriented).

Techniques newly emphasized for recruiting general population participants such as partnering with retail pharmacies, using decentralized trial approaches, and employing DHTs and social media to recruit and retain participants can also be tuned to ensure diversity.