# 5 Platforms and statistical innovation in clinical trial design

Because of the urgency to identify viable COVID-19 treatments, some clinical trials implemented previously underused approaches such as adaptive (often Bayesian) statistical analysis and platform frameworks. Key definitions are briefly provided here, with additional detail available in Appendix A.

## Utilization of platforms and statistical innovation in clinical trial design during COVID-19

Adaptive trial design, Bayesian statistical analysis, and platform trials helped accelerate the evaluation of multiple therapeutic candidates while also satisfying regulatory requirements for drug safety, characterization, and evaluation (Abani et al., 2022; Butler et al., 2023). A small number of platform trials evaluated individual agents against common (or shared) control arms (Lundgren et al., 2021; Files et al., 2022; McLeod et al., 2023). These trials often also performed frequentist interim analyses, Bayesian statistical assessments, or both.

Although many conventional (i.e., single-product, frequentist) trials were rapidly established and enrolled hundreds of thousands of participants during the COVID-19 pandemic, novel trial designs—namely those with platform approaches or adaptive elements—comprised a comparatively small fraction of overall enrolled randomized controlled trial (RCT) subjects (LaVange et al., 2021; Lundgren et al., 2021; Files et al., 2022; Higgins et al., 2023; Naggie et al., 2023). Despite the small number of participants enrolled in such trials, platform trials generated most of the evidence on effective COVID-19 therapeutics (ATTACC Investigators et al., 2021; Gordon et al., 2021; RECOVERY Collaborative Group et al., 2021) and identified likely ineffective COVID-19 treatments (Naggie et al., 2022; McCarthy et al., 2023).

### Platform trials

Platform trials are open-ended trials that occur under master protocols, facilitating the addition, evaluation, and elimination of trial arms/candidates without specifying timing parameters. Unlike a traditional RCT that tests a single intervention and typically ends (i.e., decommissions its trial operations, data collection, and associated infrastructure) when the study is complete, platform trials are RCTs that keep the trial active over longer periods via amendments to the master protocol while other sub-studies (trial arms) continue or have been completed. Unlike single-intervention-oriented trials, in which a drug is compared with standard care or a placebo, a platform trial is typically disease-centric, determining what therapy is optimal for a given indication or sub-population.

Platform experts have highlighted that the core advantage of the platform approach is that a product can be quickly added for testing through a modular amendment to an existing master protocol, resulting in more efficient trial initiation and execution within a broader ecosystem of ongoing clinical research. Platform trials have the potential to accelerate and streamline knowledge generation across indications and patient populations, but they are inherently more statistically and organizationally complex to set up and manage. Research suggests that, despite higher up-front costs and set-up times, platform trials might lead to an overall cost reduction for individual agent evidence generation (Park et al., 2022). The prevailing biopharmaceutical research and development funding models, however, do not create strong incentives for more widespread platform trials (Park et al., 2022), a sentiment echoed in expert interviews.

"From the scientific perspective, it is difficult to find trials where the platform is not useful."

- Clinical trialist

### Adaptive trial design

Adaptive trial designs allow for prospectively planned modifications to one or more aspects of the design based on accumulating data from subjects in the trial. Adaptive trials build in flexibility as they use a design-review-adapt-conduct-analyze process rather than a traditional RCT process of design-conduct-analyze (Pallmann et al., 2018).

Adaptive trials may evaluate single agents or multiple agents in parallel (adaptive platform trial). For example, single agent designs involve one intervention (simplifying the assumptions or methods that can be used), and multiple agent designs assess multiple interventions (e.g., therapies) where the toxicity curve or other properties may not be well understood, defined, or both. Adaptive single-agent designs were used in COVID-19 studies earlier in the pandemic, whereas adaptive multi-agent platform trials were mostly employed in later COVID-19 pandemic stages after clinicians and researchers established the needed infrastructure (Butler et al., 2021, 2023; Abani et al., 2022).

During the COVID-19 pandemic, a subset of clinical trials simultaneously evaluated multiple therapeutics using adaptive platform trials to rapidly identify promising treatments for COVID-19, changing clinical management of COVID-19 worldwide (RECOVERY Collaborative Group et al., 2021; Butler et al., 2023). Investigators leveraged trial coordination resources, data collection frameworks, robust national data registries (when available), and public health infrastructure (Angus, Derde, et al., 2020; RECOVERY Collaborative Group et al., 2020; Griffiths et al., 2021; LaVange et al., 2021; Yu et al., 2021; Reis et al., 2022; Butler et al., 2023). In one example, the U.K. RECOVERY platform trial randomized more than 48,496 COVID-19 patients to nine treatment groups with a single shared standard of care control group ([Abani et al., 2022], Box 7). Platform trials also generated evidence that identified marginally efficacious or non-efficacious COVID-19 treatments, and, according to one interviewed platform expert, this evidence aided in the de-emphasis or removal of these treatments from standard of care guidelines. One expert noted that, from the thousands of registered COVID-19 trials, four platform trials generated about 90% of evidence for COVID-19 treatments recommended by FDA or clinical organizations. The literature provides no exact quantification of this impact.

In the literature on adaptive trials from before the COVID-19 pandemic, one evaluation compared conventional and adaptive protocols for 29 trials and found 62% of adaptive trials completed with time savings compared with non-adaptive designs. Overall, trials saved 56 days on average by employing an adaptive approach (Lorch et al., 2012). During the COVID-19 pandemic, new data on the efficiencies associated with adaptive platform trials emerged. In the REMAP-CAP trial, trialists stopped two arms, convalescent plasma and corticosteroids, early with only N = 2,011 and N = 403 participants enrolled (Angus, Derde, et al., 2020; Higgins et al., 2023). In the same adaptive platform trial, trialists enrolled the lnterleukin-6 receptor antagonist arm to successful completion with 401 participants (REMAP-CAP Study Investigators, 2021). It is important to note that the REMAP-CAP investigators cited the RECOVERY results as the reason for their closing of these trial arms, demonstrating organizational adaptiveness to redirect resources to other sub-studies rather than to dogmatically add evidence to a resolved research question (REMAP-CAP, no date). Although both arms stopped, doing so helped liberate and redirect resources and participants to other viable candidate therapeutics and optimize COVID-19 patient treatment guidelines.

Trialists cited COVID-19 adaptive platform trials as more efficient per evaluated candidate product (operationally streamlined) and more informative per participant (fewer participants required to detect futility or a given effect size) compared with traditional fixed trial designs (Angus, Berry, et al., 2020; Griffiths et al., 2021; Yu et al., 2021; Files et al., 2022; Butler et al., 2023; I-SPY COVID Consortium, 2023). In the case of the AGILE adaptive platform trial, investigators cite the seamless ability to expand their existing Phase I platform, where the compound's dose was established, into a Phase II to confirm efficacy of a promising compound (Griffiths et al., 2021). One adaptive trial expert indicated adaptive platform trials offer a more efficient ecosystem, in which both negotiation and organization are performed upfront, which makes the conduct of specific trial arms highly efficient. This echoes comments from clinical trial operations experts, who cited aspects of standardization and upfront clarity as drivers of efficiency in clinical trials in other contexts.

Of note, most adaptive platform trials for COVID-19 products did not occur in the United States and did not evaluate compounds on the U.S. population. When asked about this geographical divide, platform trial experts indicated that the United States did not have the integrated health care infrastructure found in some other countries. For example, the U.K. RECOVERY trial identified and randomized patients using electronic health records (EHRs). Such integration enabled swift, efficient, large-scale randomization of patients into each of the treatment arms in parallel with real-time data collection from the EHR.

Adaptive trials, platform trials, or both can be used across all phases of research and through the evaluation of compounds across any context. There are specific upfront costs associated with adaptive platform trials, including data and IT infrastructure needs that typically far exceed those of a more traditional frequentist trial. For example, infrastructure is needed to isolate the results—both interim and final—from different arms of an adaptive platform trial. Different arms of a platform trial will often have different sponsors, which, for various reasons, do not want their data shared with other platform participants or are apprehensive about head-to-head comparisons of their product (e.g., a therapeutic) with that of others being tested on the same platform. Notably, in our environmental scan, no diagnostic technologies were evaluated using either of these trial design paradigms. Two different experts in platform and adaptive trial design spoke to the catalytic effect that platforms necessitate all—seemingly disparate entities—to come together and trust each other.

For illustrative purposes, summary points of comparison between traditional frequentist trials and adaptive platform trials are available in Box 6.

Box 6 Traditional trials versus adaptive platform trials

Drawbacks of conventional (frequentist) randomized controlled trials | How does an adaptive platform trial address or improve on this?
- Typically only tests one therapy or has one treatment arm | - Multiple study arms envisioned from the start with a platform trial; - Multiple therapies can be tested in tandem
- Trial statistical experts cannot use data collected in the trial to inform the trial’s ongoing activities | - Trial statistical experts can assess interim data at predetermined trial milestones for futility and to alter trial design while continuing the trial
- Potential mismatch with “precision” research, in which therapies are increasingly specific to patient subtypes | - Better able to evaluate disease subtype responses to therapies
- Requirement to pay fixed costs related to trial infrastructure for each additional RCT | - Can spread such fixed costs across multiple agents and (often a growing number of) trial arms
- Extensive delays related to start-up activities between trial phases are common | - Seamless trial designs allow products to flow through trial phases more quickly and accumulate statistical power

### Bayesian statistical analysis

Bayesian analysis is an approach for learning from evidence as it accumulates. Bayesian statistical analysis incorporates prior knowledge about a treatment effect in its statistical inferences (McCreary et al., 2022). In traditional (frequentist) clinical trials, statistical methods might use information from previous studies only at the design stage. Then, at the data analysis stage, the information from those previous studies is considered to be a complement to, but not part of, the formal analysis. In contrast, the Bayesian approach uses Bayes' theorem to formally combine prior information with current information on a quantity of interest. Bayesian approaches can reduce clinical trial sizes and enhance trial speed (Saville and Berry, 2016). A risk of Bayesian analysis is that studies of the same research question might generate different a priori probability distributions (patient population by therapy), resulting in distinct or even conflicting conclusions. Bayesian approaches have their own regulatory guidance document for planning, statistical analysis plans, and submissions compared with frequentist analysis, most of which was seen in the medical device space pre-COVID-19 (U.S. FDA Bayesian, 2018; U.S. FDA Adaptive, 2020; Ruberg et al., 2023).

Adaptive study designs typically use Bayesian analysis to facilitate an agile trial process, allowing for the rapid evaluation of multiple hypotheses across varying indications and therapies, leading to more efficient futility analyses and identification of promising candidates and a dynamic shift for patient recruitment to accelerate evidence for those promising candidates. At least 80 COVID-19 clinical trial publications include Bayesian analysis (World Health Organization, 2023). One example is the I-SPY COVID adaptive platform trial, which incorporates Bayesian stopping or graduation rules to efficiently halt ineffective candidates or to progress promising therapies (Files et al., 2022). Stopping futile arms can save time, liberate resources, and decrease the number of patients who would otherwise have been enrolled in a futile trial arm. Researchers also used Bayesian survival regression models to model the hazard functions for the two events of interest: (1) recovery (treating death as a competing event) and (2) overall death from COVID-19. Bayesian proportional-hazard Weibull models simulate outcomes (i.e., the cause-specific hazard function for recovery, treating death before recovery as a competing event, as a function of study arm), and adjusted for baseline COVID-19 level at a given moment in the COVID-19 pandemic. Importantly, in such a study design, the control group is chosen from the same population as the investigational agent group, which, because of the potential of evolving real-time recovery and fatality rates in an ongoing pandemic, potentially enables more optimal control comparison as opposed to the alternatives (Files et al., 2022).

In a direct comparison of Bayesian and frequentist interventional approaches, two trials evaluated the potential impact of therapeutic dosing of the anticoagulant Heparin on patients with COVID-19 rather than the standard of care, which used the typical lower doses of Heparin. In a collaborative effort between the REMAP-CAP, ATTACC, and ACTIV-4a platform trials (ATTACC Investigators et al., 2021), randomization to Heparin began on April 21, 2020. After 276 days and 1,181 Heparin-treated patients, on January 22, 2021, the data and safety monitoring boards advised enrollment be discontinued for a planned adaptive analysis of data from 1,398 patients. The analysis revealed that the prespecified stopping criteria for superiority of a therapeutic-dose anticoagulation had been met. In contrast, in the HEP-COVID trial, which followed the classic RCT framework and frequentist statistical analysis, 130 patients were randomized to therapeutic dose Heparin between May 8, 2020, and May 14, 2021 (371 days) (Spyropoulos et al., 2021). HEP-COVID, like the REMAP-CAP, ATTACC, and ACTIV-4A trials, found that in non-critically ill patients hospitalized with COVID-19, therapeutic dose anticoagulation with Heparin increased the probability of survival (ATTACC Investigators et al., 2021). The Bayesian platform framework reached this conclusion in 74.4% of the time and with 9.1x the study participants of the RCT frequentist approach.

Other COVID-19 treatment trials maximized Bayesian primary analysis models to use previous enrollments in the standard-of-care arm of a trial to increase the precision of efficacy estimates, which allowed the trialists to declare futility with high precision because of low probability of a meaningful benefit of a given compound on time to recovery (ATTACC Investigators et al., 2021). Employing a Bayesian approach allowed trialists to drop ineffective arms (in the case of both REMAP-CAP and RECOVERY, two arms) and to efficiently and quickly allocate limited trial resources to other interventions.

There is little to no publicly available quantitative evidence of cost savings based on Bayesian analyses (opposed to frequentist) through either simulations, controlled trials, or observational studies during the COVID-19 pandemic. Yet simulations conducted before the COVID-19 pandemic suggested adaptive Bayesian trials might require less than half the participants and time that traditional frequentist two-arm trials require (Saville and Berry, 2016). Such trials also come with additional setup costs and unique needs that are not seen in other trials, such as the data and IT infrastructure needed to build firewalls between sponsors and trialists to manage protocol-compliant interim analyses and a much greater demand for computational power to run simulations. Future action could aim to quantify cost comparisons and other tradeoffs that are unique to Bayesian trials to direct future trial strategies.

"The COVID-19 pandemic was good for teaching us how platform trials can be successful and showing us that a Bayesian approach is probably the right way for the analytical approach."

- Clinical trialist

### Case Study: U.K. RECOVERY versus U.S. NIH ACTIV adaptive platform trials

Although there were several platform trials established during the COVID-19 pandemic, a comparison of the U.K. RECOVERY platform (Box 7) with the NIH ACTIV platform demonstrates that platform trials can differ in their speed and ability to enroll, which is highly correlated with the pre-pandemic medical information and clinical research infrastructure available to each. Both RECOVERY and NIH ACTIV evaluated aspirin and convalescent plasma as potential COVID-19 therapies.

For aspirin, the RECOVERY trial enrolled and dosed 7,351 participants in 140 days (November 1, 2020, to March 21, 2021) compared with 164 patients enrolled in 273 days (September 2020 to June 2021) in NIH ACTIV (Connors et al., 2021; Abani et al., 2022). It is important to note, however, that investigators stated that the NIH ACTIV trial arm for aspirin was stopped early because of an unanticipated low event (COVID-19) rate, to which the low enrollment might have contributed (Connors et al., 2021). RECOVERY recruited 44.8x times more participants into its aspirin study in about half the time as compared with NIH-ACTIV.

For convalescent plasma, NIH ACTIV initiated three sub-studies assessing convalescent plasma, compared with a single RECOVERY sub-study. RECOVERY enrolled and dosed 5,795 patients in 232 days (May 28, 2020, to January 15, 2021) (Abani et al., 2021). The first NIH ACTIV sub-study enrolled 468 patients in 346 days (April 17, 2020, to March 29, 2021) (Ortigoza et al., 2022). The second NIH ACTIV sub-study, PassItOn, began only a week later, enrolling 438 patients in 438 days (April 24, 2020, to July 6, 2021) (Self et al., 2022). The final NIH ACTIV sub-study, C3PO, was initiated five months later and enrolled 257 patients in 230 days (August 11, 2020, to March 29, 2021) (Korley et al., 2021). Compared with the third NIH ACTIV convalescent plasma sub-study, RECOVERY enrolled 22.5x more participants in nearly the same number of recruiting days (232 versus 230). The other two NIH ACTIV convalescent plasma trials required 1.49x and 1.89x longer to each enroll only 8% of the number of participants that RECOVERY enrolled.

Although the NIH ACTIV sub-studies often began before their respective RECOVERY trial arms, RECOVERY enrolled far more patients in the same or fewer days. RECOVERY had the advantage of leveraging the U.K.'s National Health Service EHR across many care delivery sites for recruitment, whereas the NIH ACTIV trial relied on narrower network study sites each using their local patient identification capabilities.

U.K. platform trials leveraged existing integrated medical records as well as an infrastructure prepared for large, distributed clinical trials, often at the point of care. Researchers and federal agencies in the United States do not have the ability to pursue either of these options at present, despite public investments of billions of dollars of into health information exchanges, electronic medical records, and trial networks.

Box 7 RECOVERY demonstrates adaptive platform trial feasibility for COVID-19 therapies

Launched in 2020, the Randomised Evaluation of COVID-19 Therapy (RECOVERY) trial is an international adaptive, multi-arm platform, open label, randomized controlled, clinical trial established to identify treatments that might benefit people hospitalized with suspected or confirmed COVID-19. The study is being conducted by researchers at the University of Oxford, which acts as the sponsor for the research, working with doctors at many hospitals across the United Kingdom. Following its U.K. launch, the trial later expanded internationally to Ghana, India, Indonesia, Nepal, South Africa, and Vietnam (RECOVERY TRIAL, 2020).

Within two years of its establishment, RECOVERY had identified four effective treatments against COVID-19 as well as 10 treatments that do not benefit COVID-19 patients:

A table listing the four effective COVID-19 therapies identified in the RECOVERY trial and the eight that were not effective. Effective therapies: Dexamethasone, Tocilizumab, Ronapreve, and Baricitinib. Eight therapies not effective: Hydroxychloroquine,, Lopinavir-ritonavir, Azithromycin, Convalescent plasma, aspirin, Colchicine, Dimethyl fumarate, and higher dose corticosteroids.

Source: RECOVERY trial website: https://www.recoverytrial.net/files/recovery-results_december-2022.png

As of July 2023, the RECOVERY trial was evaluating two additional suggested treatments for COVID-19 and three for influenza to discern whether they are more effective in helping people recover than the standard care that all patients receive (RECOVERY TRIAL, 2020). At the time of the report writing, RECOVERY had 190 active sites and had enrolled more than 48,564 participants into the trial.

Initial funding for the trial was provided by a grant to the University of Oxford from U.K. Research and Innovation and the National Institute for Health Research along with core funding provided by the National Institute for Health and Care Research (NIHR) Oxford Biomedical Research Centre, the Wellcome Trust, U.K.'s Department for International Development, Health Data Research U.K., the Medical Research Council Population Health Research Unit, National Institute for Health and Care Research Clinical Trials Unit support funding, and the Bill and Melinda Gates Foundation, which pledged more than $250 million to the global COVID-19 response, in particular to support African and South Asian countries to roll out detection, treatment, and isolation programs (RECOVERY TRIAL, 2020).

The RECOVERY Trial is registered at ISRCTN50189673 (http://www.isrctn.com/ISRCTN50189673)

EU Clinical Trials Register: EudraCT 2020-001113-21 (https://www.clinicaltrialsregister.eu/ctr-search/trial/2020-001113-21/GB)

Clinical Trials.gov: NCT04381936 (https://clinicaltrials.gov/ct2/show/NCT04381936)

### Challenges and opportunities for more widespread adoption of adaptive and platform trials

Multiple experts spoke about the challenges of employing platform and adaptive trials under pandemic conditions. One expert said that, theoretically, platform approaches can work for every product, but creating the infrastructure, governance, and connections to regulators requires time to build multi-party alignment and then the operational capabilities. When these pieces were already in place, platforms performed well. The lesson for future pandemics is that infectious disease platform trials should be operationally tested, already be operational at some level, and have capacity expansion plans in place to fulfill their potential for the future.

Experts identified multiple practical challenges to more widespread adoption of platform trials and adaptive trial designs, including the following:

- Platform trials require sponsors to commit their drug and vaccine development programs to standard outcomes metrics and comparisons that might diminish product distinctiveness. Tools such as verified IT solutions and regulatory guidance on best practices can only partially address sponsors' concerns regarding head-to-head comparisons between products on the same platform. Accepting the costs and benefits of this approach will require culture change, and commercial and operational risks may remain.
- Traditional publication processes are not designed to accommodate adaptive trial designs or platform trials and can be overly cumbersome for corresponding/lead author investigators. Authors generally have to repeatedly submit and review master protocol elements rather than leveraging platform trial commonality among sub-studies and arms.
- Adaptive and platform trial expertise among regulatory reviewers is needed across all FDA centers and divisions. Because these approaches have historically been adopted by some therapeutic areas more than others, not all FDA centers and divisions have built the expertise or implemented review strategies appropriate for these emerging clinical trial approaches.

Individual FDA guidance documents have recommended a set of practices for using adaptive or Bayesian statistics, establishing master protocols and platform trials, incorporating decentralized approaches into clinical protocols, and deploying DHTs in clinical development. Each provides significant clarity, and, in combination, they have facilitated successes such as the point-of-care REMAP trials, rapid diverse enrollment in COVID-19 vaccine trials, and the standing up of therapeutic platform trials such as NIH-ACTIV and, to a lesser extent, the U.K. RECOVERY platform trial. With ongoing leadership, especially to overcome organizational and business model inertia, positive innovative synergy in industry- and government-sponsored trials could continue.

## Lessons Learned for platforms and statistical innovation in clinical trial design

During the COVID-19 pandemic, platform trials proved highly effective in generating actionable evidence for COVID-19 candidate therapeutics. Nevertheless, the speed and efficiency gains varied across platform types. Infrastructure differences, from governance to technical, have since emerged as important contributing factors to this variance.

Bayesian statistics demonstrated speed and power advantages compared with traditional designs for generating comparable results with fewer enrolled participants. In the future, the value of such efficiencies will be particularly salient in a pandemic setting, but they also can be realized in non-emergency settings as well. Against this backdrop, experts reported that ongoing conversations and transparency between and among trialists and regulators enables implementing clinical trial design innovations. While generally true, pandemic circumstances exacerbate the need for dialogue and transparency and highlight the need for collaborative personnel cross-sharing to speed the process. In particular, because sponsors perceive risks in adopting innovative designs, regulatory guidance documents can partially address sponsor concerns; however commercial and operational risks may remain. Accepting the risks of innovative designs and adopting these approaches more broadly will also require culture change among sponsors. Aligning regulatory staff reviews and expertise with these innovative trial designs may also streamline the review process, particularly in urgent scenarios.

Looking ahead to future efforts to enable pandemic preparedness, infrastructure investments emerge as a key enabling factor. Pandemic response requires pre-existing platform infrastructure for both EHR access to support participant recruitment and endpoint tracking as well as clinical research infrastructure to generate the time-urgent evidence that public health emergencies need. The United Kingdom demonstrated the value and speed such capability can deliver—capabilities that were largely absent in the United States and time consuming to create, especially during a pandemic.