# 4 Decentralized clinical trials and digital health technologies

A decentralized clinical trial (DCT) is a clinical trial in which some or all trial-related activities occur at locations other than traditional clinical trial sites (e.g., enabling patients to participate from their homes or local health care facilities; U.S. FDA DCT, 2023). DCTs may use software applications and digital solutions, such as those categorized as DHTs by FDA (U.S. FDA DHT, 2023), to allow real-time data collection and remote patient monitoring. Boxes 1 and 2 provide additional information and examples of DCTs and DHTs.

Box 1 Decentralized clinical trials

A decentralized clinical trial (DCT) refers to a clinical trial where some or all of the trial-related activities occur at locations other than traditional clinical trial sites. In fully DCTs, all activities take place at locations other than traditional trial sites. These trial-related activities may take place at the homes of trial participants or in local health care facilities that are convenient for trial participants. In hybrid DCTs, some trial activities involve in-person visits by trial participants to traditional clinical trial sites, and other activities are conducted at locations other than traditional clinical trial sites, such as participants' homes. Potential advantages of DCTs include the following:

- Ability to include patients in rural areas, patients from underprivileged geographies, or those with limited travel possibilities
- More flexibility for patients, which in turns leads to higher retention and better satisfaction with the trial participation
- Helps prevent missing data
- Can be performed at larger scale, spanning across centers and countries to enhance diversity and robustness of trials

Source: U.S. Food and Drug Administration (U.S. FDA DCT, 2023)

Box 2 Digital health technologies

Digital health technologies (DHTs) offer many potential benefits in the development of medical products, including drugs. Advances in DHTs, including electronic sensors, computing platforms, and information technology, provide new opportunities to obtain clinical trial data directly from patients. Portable DHTs that may be worn, implanted, ingested, or placed in the environment allow real-time collection of data from trial participants in their homes or at locations remote from clinical trial sites. Potential advantages of these DHTs include the ability to do the following:

- Make continuous or frequent measurements of clinical features
- Record or measure novel clinical features that could not be captured during traditional study visits
- Decentralize clinical trial activities by obtaining clinical data from study participants remotely

Source: U.S. Food and Drug Administration (U.S. FDA DHT, 2023)

Despite considerable interest in DCTs over the past decade, before the COVID-19 pandemic, their application had remained limited to smaller studies or secondary measurements (Spinner, 2022). Only a few trials were executed in a fully decentralized manner before the pandemic (Roehr, 2011; Ho et al., 2017; Sommer et al., 2018). The onset of the COVID-19 pandemic, together with the emergency constraints, social distancing requirements, travel restrictions, and shifts in the availability of hospital resources, created significant challenges for standard clinical trial operations, threatening closure of ongoing trials and delays in the new trial initiations (see Chapter 3, Disruptions to clinical trials due to COVID-19 for more detail). Under these circumstances, decentralized approaches and use of DHTs emerged as promising solutions to ensure continuity of ongoing trials and to enable initiation of new trials, including COVID-19 vaccine studies (Agrawal et al., 2021; Lee et al., 2021; Parkins, 2021; Aitken, Connelly and Leamy, 2022; Moore et al., 2022). Box 3 presents some of the key opportunities created by DHTs in the space of clinical trials.

Box 3 Opportunities created by digital health technologies

Digital tools (e.g., mobile devices, mobile apps, remote monitoring devices, and online social engagement platforms) can be incorporated into study designs for some novel benefits, including the following:

- Improving trial participant recruitment and retention (speeding results, lowering costs for sponsors), including improving trial participant diversity
- Possibly improving trial participant retention, which may reduce missing data, shorten timelines, and improve data interpretability
- Enabling online-based informed consent
- Tracking adverse events
- Providing greater control, convenience, and comfort for participants by allowing them to contribute from home rather than traveling to a trial site, which can, in turn, increase engagement
- Possibly enabling continuous real-time data collection of endpoints (rather than periodic data collection during site visits)

Source: National Academies of Sciences, Engineering, and Medicine; Health and Medicine Division; Board on Health Sciences Policy; Forum on Drug Discovery, Development, and Translational Health (NAS et al., 2019)

## DCT and DHT Implementation during COVID-19

In March 2020, FDA released a guidance document regarding the conduct of clinical trials during the COVID-19 Public Health Emergency (Turner, 2020; U.S. FDA Conduct, 2021). This document provides practical advice for ensuring participants' safety, maintaining data integrity, and accounting for pandemic-related variability in trial protocols. It advocates for remote and decentralized trial methods, offering detailed considerations and recommendations for their implementation and integration into the study when appropriate. An expert on vaccine development pointed out that strong guidance documents from FDA early in the pandemic (Turner, 2020; U.S. FDA Conduct, 2021) helped many trials finish during COVID-19 pandemic and observed that some that did not follow recommendations struggled.

Two experts spoke of the challenges of referring to decentralized trials as a "separate category" of trials, instead emphasizing that decentralized elements and DHTs can be incorporated into a multitude of trials and trial designs to drive efficiencies and patient centricity. For example, even a fully inpatient trial might achieve more efficient and more patient-centric enrollment by designing an electronic informed consent (eIC) process that incorporates educational videos and interactive elements. Using these strategies to reduce on-site visits also benefits sponsors because of their high costs for clinical staff and significantly higher time burdens for participants.

Over the course of the COVID-19 pandemic, DCTs and DHTs saw effective use during various stages of the clinical trial. The implementation of these tools is described by trial stage below.

Trial recruitment, enrollment, and informed consent: Digital tools have long allowed patients to complete pre-screening, consultation, and informed consent through video-meetings or virtual platforms, but these approaches were leveraged more frequently during the COVID-19 pandemic. Although many non-COVID-related trials faced disruptions and delays in recruitment, those that had incorporated digital and decentralized strategies from the beginning were able to proceed and sometimes even benefit from the situation. For example, the "Intuition" study (ClinicalTrials.gov identifier: NCT05058950 (https://clinicaltrials.gov/ct2/show/NCT05058950)), an observational study using multimodal sensors to measure cognitive health in adults and detect mild cognitive impairment launched in January 2021, was designed to be remote and managed to recruit thousands of participants within the first three months. The surge in enrollment could be attributed, in part, to the COVID-19 pandemic because people who might have otherwise been involved in different studies opted to join the INSIGHT study. Other strategies to meet the patients where they are included the engagement of retail pharmacies, such as Pfizer's partnership with Walgreens to allow patients to conveniently enroll in the Paxlovid trial (ClinicalTrials.gov identifier: NCT05576662 (https://clinicaltrials.gov/ct2/show/NCT05576662)) while picking up their prescriptions (Grabenstein, 2022). These examples further underscore the importance of a patient-centric approach in increasing clinical trial participation.

Sponsors facilitated eIC through online portals, mobile apps, secured emails, or text messaging (Josan et al., 2021; Lee et al., 2021; U.S. FDA Conduct, 2021). These approaches were used to not only reach patients at their homes but also drive enrollment of intensive care unit patients, as non-clinical staff were frequently barred from entering patients' rooms or hospitals. The COVID-19 experience also highlighted the importance of a well-designed—often multimodal—eIC process, in which standard consent forms and language are enhanced by infographics, videos, links to learn more, Slack support groups, and multiple language options to improve patients' experience and comprehension. Independent experts cited better retention of information and higher patient satisfaction with the enhanced versions of consent procedures compared with the standard approach to decentralized/remote patient consenting of a 20-minute phone call. More importantly, enhanced forms of informed consent processes have been shown to empower people who were historically underrepresented in clinical studies, as witnessed in the All of Us study, which uses such approaches to enroll a group of participants that "reflects the diversity of the United States" (All of Us, 2020).

Treatment and monitoring: To minimize barriers to patient recruitment and participation, several experts highlighted the importance of patient-centric data collection; this includes accommodating participants by facilitating remote data collection outside the clinical setting. The experts saw this as a vital approach under all circumstances but particularly imperative during the COVID-19 pandemic, when patients could not or did not want to travel to clinical sites. The logistical challenges of conducting clinical trials amid a pandemic led to the adoption of several decentralized trial elements for clinical trial operations, often enhanced by DHTs. These include the following:

- Telemedicine, the remote delivery of health care services, played a crucial role in substituting in-person visits and ensuring the continuity of clinical trials during the pandemic. It encompassed various trial aspects, including virtual clinician visits, patient monitoring, symptom reporting, and virtual pill-taking (medication adherence monitoring through home delivery coupled with video conferencing software).
  Although telemedicine existed in the United States before COVID-19, its use was significantly constrained in clinical care delivery and research. These constraints included limited reimbursements, underdeveloped digital infrastructure, ambiguities in IRB jurisdiction (for some federally funded research), other regulatory variations across states, and restrictions on cross-state health professional licensing (Apostolaros et al., 2020; Lee et al., 2021).
  To ease these barriers during the COVID-19 pandemic, the Centers for Medicare & Medicaid Services issued waivers to grant payment parity between telehealth and in-person care, and the Office for Civil Rights exercised enforcement discretion (and effectively halted the use of penalties) for use of technologies that did not comply with the Health Insurance Portability and Accountability Act (HIPAA) (e.g., Zoom, Skype, and FaceTime) to provide telehealth services (Baumann, MacArthur and Michalski, 2020; Shachar, Engel and Elwyn, 2020; De et al., 2021; Schofield, 2021; HHS HIPAA, 2022). In addition, some states provided emergency licensing waivers, which alleviated the burden of cross-state licensure requirements (Federation of State Medical Boards, no date). Although these policies were not universally adopted across the United States, they expanded the deployment of telemedicine in clinical practice as well as in clinical trials—not only for research and care associated with COVID-19 but also for other diseases (Freedberg et al., 2020; Hatcher-Martin et al., 2020; HHS, 2020; De et al., 2021; Josan et al., 2021; Greenough et al., 2022; Kaizer et al., 2023).
  All the interviewed experts agreed that the COVID-19 pandemic demonstrated that many aspects of clinical trials can be effectively performed remotely—a belief long held by the DCT community but previously not widely adopted. The experts also agreed that, to harness the benefits of telemedicine for clinical trials outside of emergency situations, greater reimbursement parity and changes in cross-state licensing regulations are necessary, especially because many COVID-19 pandemic policies (at local, state, and national levels) have been reversed since the end of the federal public health emergency in May 2023.
- Self-monitoring and at-home measurements: During the COVID-19 pandemic, many sponsors opted to send measuring devices, such as blood pressure monitors, spirometry tools, or glucose monitoring devices, directly to patients' homes for self-monitoring to substitute for (some) in-person clinical site visits. Their use during the COVID-19 pandemic revealed that patients were capable of effectively using these at-home measuring devices. One expert referred to a PROGRESS study in which patients were offered an option of at-home visits or self-guided at-home testing to perform glucose monitoring. The vast majority (>90%) of the participants chose self-guided at-home testing, allowing the trial's leaders to shift some study coordinators' time to other work. The possibility of reducing at-home visits also creates potential for cost reduction and resource optimization. This trial includes a patient-centric approach that acknowledges the diverse range of patient preferences and comfort levels, fostering inclusivity regardless of participants' technological literacy.
  Certainly, activities such as neurological evaluation, neurocognitive or joint mobility assessment, and radiology scans require nuanced clinical judgment and expertise that patient-reported outcomes or at-home measurements cannot easily capture in the absence of a clinician. Moreover, concerns about the discrepancies between at-home and ambulatory clinic measurements remain. Still, it’s possible some at-home measurements might capture data in the context of a patient’s daily routines and natural behaviors, providing more true-to-life evidence on disease progression, symptoms, and side effects. Some discrepancies could be potentially reduced through telemedicine to supervise patients during the measurements. Others will inevitably remain, and ongoing research is necessary to validate at-home measurement tools and the measures they collect.
  Interviewed experts agreed that despite these uncertainties, there remains significant value in leveraging at-home measurements tools and that such approaches can and should be leveraged on an ongoing basis to substitute for select in-patient visits. A combination of ambulatory clinic and at-home measurements could be what one expert called the "goldilocks" solution, offering greater flexibility to patients and better accounting for real-world evidence (RWE) and maintaining oversight and the broad integrity of the trial's findings.
- DHTs were used for remote patient monitoring and data collection during the COVID-19 pandemic. For example, to monitor COVID-19 patient recovery or cardiac safety signals, some patients were allowed to use wearable devices and mattress sensors to track their vital signs such as heart rate, respiratory function, body temperature, sleep patterns, and movement. This continuous monitoring resulted in data reflecting the patient’s everyday status and could alert health care professionals of new side effects and symptoms (Seltzer et al., 2022; Von Preyss-Friedman et al., 2022). Trials also employed custom mobile applications, such as a medication adherence app that reminded patients to take their medication, specified the dosage, tracked missed doses, and provided refill notifications (Dockendorf et al., 2021; Volpi et al., 2021). Other digital tools included symptom tracking apps and eJournals that recorded symptoms and patients' experiences in real time, as opposed to the retrospective reporting normally collected in person during hospital visits (Drury and O'Connor, 2021; Houhamdi and Fournier, 2022; Pandit et al., 2022). Although DHTs hold promise for clinical research, trials using DHTs must ensure that patients have prior training or digital proficiency when reporting their symptoms and validate their methods so that they can maintain the integrity of these measurements (Hashem et al., 2020; Inan et al., 2020).
- Trials leveraged local medical centers and mobile units for interventions unsuitable for virtual conduct. In many trials, mobile units (e.g., phlebotomists) collected biological samples directly at patients' homes. For instance, the Healthy-Lung trial (ClinicalTrials.gov identifier: NCT04798664 (https://clinicaltrials.gov/ct2/show/NCT04798664)) accomplished two-thirds of its sample collections through mobile units, offering safer alternatives to on-site visits during the COVID-19 pandemic. An expert specializing in DCTs emphasized that despite the higher costs involved, the use of mobile units significantly simplifies patient participation in the trials and provides an additional tool to augment the diversity of participants.
  Clinical trial activities that required medical site visits, such as radiotherapy and imaging, were often conducted in collaboration with local medical centers (Izmailova, Ellis and Benko, 2020; Ali et al., 2021; Anderson, 2021; Boughey et al., 2021; De et al., 2021; Park et al., 2022). As with all multisite trials, this collaboration necessitated substantial harmonization of practices to address the variability in medical devices and protocols used across the health centers. Another innovation incorporated during the pandemic was allowing community pharmacists and local health centers to administer medications or delivering medication direct to patients (National Cancer Institute, 2020; Waterhouse et al., 2020; McDermott and Newman, 2021; Sami et al., 2021; Van Norman, 2021; Mohamed Ibrahim et al., 2022; Pantasri, 2022; Kaizer et al., 2023). Handling of medication outside of a centralized trial site requires additional oversight, detailed protocols, and close monitoring to ensure participants' compliance and drug stability and appropriate storage (e.g., temperature tracking). Precautionary measures also had to be implemented to prevent unauthorized medication access and to ensure timely refills to prevent study interruptions (National Cancer Institute, 2020; Van Norman, 2021). Beyond emergency conditions, involvement of local health centers and direct-to-patient delivery could serve to improve accessibility to clinical trials, benefiting patients from rural areas or those with limited travel possibilities.

With the conclusion of state public health emergency declarations beginning in 2021, and the federal public health emergency concluding in May 2023, certain regulatory waivers and flexibilities were reversed (Cox et al., 2023; U.S. FDA Staff, 2023). For instance, some states discontinued cross-state licensing waivers (Licensing across state lines, no date), and the use of HIPAA-compliant technologies became a requirement for virtual patient encounters (HHS HIPAA, 2022; Cox et al., 2023). Notably, certain platforms such as Zoom have updated their services to provide HIPAA-compliant solutions (Zoom, 2021; Alder, 2023). Significant aspects of telemedicine, such as payment parity, waiver of geographic and location requirements, and the in-person visit requirement for initiating tele-behavioral health services, were extended until December 31, 2024 (U.S. FDA Staff, 2023; HHS Fact Sheet, 2023).

### Considerations for special populations: lessons from oncology and rare disease trials

Given the typical geographic dispersion of patients with rare diseases,^3^ some trials of therapies for these conditions were already designed to incorporate decentralized elements before the COVID-19 pandemic. Interviewees and a 2023 study reported that these trials experienced fewer or less severe disruptions during COVID-19 (Miller and Miller Needleman, 2023). A 2020 McKinsey survey of 20 cell and gene therapy companies in Europe found that 55% of organizations paused site activations and enrollment visits (Loche et al., 2020). Because of the inherent paucity of participants for rare disease trials, interventions to salvage trials and facilitate ongoing research were seen as particularly valuable. Companies used DHTs to collect data when possible, which helped trial leaders use other resources efficiently during the COVID-19 pandemic. In addition, an expert in the development of therapies for patients with rare diseases noted that there have long been numerous support programs to get patients to study sites, including travel grants for participants and families, but the funding for these programs and existing collaborations with patient advocacy groups were further expanded during the pandemic.

Oncology trials were dramatically impacted by COVID-19, with one analysis finding that 95% of clinical trials in the space were suspended at the beginning of the COVID-19 pandemic (Wilkinson, 2021). Of the trials that managed to navigate the COVID-19 period, many relied on tools facilitated by existing regulations and regulatory guidance documents, including eIC from participants, drawing blood close to the patients' homes (rather than at a central study site), and remote monitoring. All of these approaches were already allowed (CTTI, 2018; Florian, Forrest and Randall, 2018; Gottlieb, 2019; Rodriguez-Chavez, 2019) and sometimes incorporated into trials, but COVID-19 accelerated their adoption. Experts cited patient registries and community support groups across various disease spaces for their role in facilitating recruitment and creating a valuable online community for patients. Patients were able to use them to find needed information and resources and communicate with others who have the same diagnoses.

### Digitization versus digital transformation

Expert descriptions of DCTs in the first year of the pandemic emphasized unplanned augmentation of existing protocols with digital tools and "bolt-on solutions" to existing trials to enable (more) remote trials. These included activities such as replacing paper consent documents and in-person meetings with eIC and virtual visits. Experts noted, however, that simply digitizing existing processes and approaches might offer limited value and, in some cases, introduce more overhead work if they are not implemented thoughtfully. An expert specializing in DCTs recounted a case in which the IRB required screenshots of all eICs in all languages, a task that necessitated 800 hours to complete and which, the expert noted, was not otherwise associated with any value-add for participants or the trial sponsor. Successful digitization of individual activities requires aligning all impacted parties, not just the direct users.

Digital transformation connects those individual innovations to broadly impact clinical trial experiences and quality. For example, experts underscored the value of making trials more participant-centric and also spoke of the importance of "giving something back" to participants, such as providing actionable data or education about their health. This reciprocity not only fosters trust but also empowers participants in their health care journey. For instance, the Johnson & Johnson-sponsored Heartline trial (ClinicalTrials.gov identifier: NCT04276441 (https://clinicaltrials.gov/ct2/show/NCT04276441)) included upfront education to the population with high prevalence of cardiac arrhythmia.

This approach allowed the entire cohort to learn and engage throughout the trial, leading to a better understanding of digital alerts and results, as pointed out by the study representative. This example stands in stark contrast to most traditional trials in which participants receive a few email updates about findings (often months after their own involvement) without tangible insights for the participants themselves. Creating value for trial participants can involve establishing social networks and communities (see Box 4), although doing so might risk sharing information that could compromise participant blinding. The pandemic demonstrated that these additional measures, which often involve minimal overhead compared with existing study procedures, can significantly enhance patients' adherence and satisfaction.

Box 4 Empowering participants and communities through clinical trials

##### The 4YouAndMe Trial

A clinical trial led by the 4YouAndMe nonprofit demonstrated an example of participant empowerment through clinical trials. The objective of the study was to determine the feasibility of COVID-19 detection before the onset of symptoms using continuous monitoring through smartwatches and aurora rings. The study recruited 1,200 nurses at intensive care units across the country; it took an innovative approach by building an entire community around the trial participants. The trial offered weekly touch points to further support the participants. The study representatives reported extraordinary adherence and positive attitude of participants toward the study involvement. The participants' positivity stemmed from the additional benefits of trial participation in the form of a social network. By fostering a sense of community, this clinical trial not only focused on the scientific objectives but also recognized the importance of participant experience and engagement. Although the community approach might not be suitable for all trials, an expert highlighted that communities already exist around rare diseases, and digital technology might provide new avenues to reach people and engage them in clinical trials.

Source: (4YouandMe, no date) and expert interview

As another example of needing to link individual innovations and reduce the burden placed on trial sites as clinical trials become digitized, experts highlighted an increasing need to create integrated and standardized systems useful across multiple trials simultaneously. Many trials demand their own technology stack, including devices, leading to site challenges with managing an overwhelming array of tools. One expert recalled a case involving a site reaching its saturation point of devices and technology, in which the site implored, "please don’t give me another tablet!" Inclusion of bring-your - own-device options could alleviate some issues and improve efficiency in the context of a public health emergency and more broadly as mobile technology becomes more ubiquitous. For instance, the DETECT trial (ClinicalTrials.gov identifier: NCT04336020 (https://clinicaltrials.gov/ct2/show/NCT04336020)) managed to recruit 41,000 participants in four weeks using a bring-your-own-device approach. An expert familiar with this trial reported large time savings, saying they distributed devices only when needed (e.g., to include people who didn’t have their own technology in underrepresented groups).

Box 5 The Michael J. Fox Foundation's virtual study demonstrates digital transformation

##### The opportunity created by digital technologies

People with and without Parkinson's disease were enrolled using The Michael J. Fox Foundation's Fox Trial Finder, a clinical trial matching tool. More than 160 participants from 39 sites spread across the country were enrolled in the study. Parkinson's disease is typically visually diagnosed. The virtual platform used in the study allowed investigators to visually examine Parkinson's disease status remotely via videoconferencing, without requiring participants to leave their homes. Furthermore, it allowed for wide geographic representation and enabled participation for those who previously had no means of doing so. In a follow-up evaluation of participants' experience, 90% of participants reported satisfaction with the trial, 80% reported they were more willing to participate in a similarly designed trial, and 85% reported they would be more able to participate if they could do so remotely.

Source: (NAS et al., 2019)

An expert well-versed in DHTs underscored that although these technologies have the potential to improve retention, their effectiveness hinges on smooth integration into patients' lives. Adopting a product-like mindset, which emphasizes functionality and a positive user experience, can prove transformative in this context. For instance, trials often require patients to navigate different gadgets, apps, and software, which can overwhelm some participants. Two experts separately suggested that a more streamlined and convenient user experience could be achieved through a unified platform that would offer multiple functionalities, including monitoring vital signals, medication reminders, appointment scheduling, and telemedicine consultations. Further, one expert noted that, for those suffering from conditions that already create daily stress and demand a high burden of ongoing management, such as long COVID-19 or multiple sclerosis, minimal interaction with DHTs and passive data collection (when possible) might be particularly valuable.

The COVID-19 pandemic subjected DCTs and DHTs to a crucial stress test, driving emergent innovations and prompting solutions that might not have been explored otherwise. Still, caution is necessary when assessing the lessons learned and cost implications of DCTs and DHTs from this period because they might not fully reflect the future landscape of these approaches and tools. The pandemic-induced transition to decentralized and digitized clinical trials was primarily driven by the urgent need to save trials from an ethical and new product development perspective rather than the result of premeditated planning and design. This abrupt transition was often associated with substantial costs, often without adequate opportunities for return on investment. As one expert put it:

"The sudden change to DCT was hard. I'm not sure if we did it in the best way; we did in the fastest way. It was sort of retrofitting—good DCTs should be designed with decentralization in mind."

- Expert on DCTs

The experts on DCTs and DHTs and those from other backgrounds consistently agreed that DCTs and DHTs offer an opportunity to reimagine clinical trials to create a higher quality participant experience and generate better, more efficient evidence for sponsors. Such a digital transformation for clinical trials requires proactively designing the novel approaches into a connected trial protocol, from patient recruitment to patient-centric monitoring to database lock, to enhance overall participant experience, sponsors' outcomes and endpoints, regulatory review, and public acceptance. Of course, participant-centric trial design means considering many relevant patient preferences in any given setting. For example, some participants might not want trial personnel coming to their homes, and others might not be comfortable with technology. As such, experts highlighted that outside of the pandemic, during which DHTs and DCTs might have been the only way to keep trials going, these approaches should be seen as just some of many ways in which clinical trials can be made more inclusive and participant centric. Any deployment outside of a pandemic should be fit-for-purpose with respect to the study and the target participant population.

### Opportunities for the future

Technology and decentralization played a pivotal role during the COVID-19 pandemic and are poised to become crucial tools for research during future public health emergencies and more broadly. Integrating DCT elements and DHTs into routine clinical trial procedures can substantially reduce emergency-related expenditures in the future.

The value demonstrated by DCTs and DHTs during the COVID-19 pandemic extends beyond emergency situations, as experts universally highlighted. Historically, clinical trial participation has been limited, with only 5% of the U.S. population participating in trials, and 70% living about two hours away from trial sites (Miseta, 2022). This challenge is compounded by dropout rates that can reach up to 30% (Miseta, 2022). Recognizing these hurdles, experts endorse DCTs and DHTs to bring clinical trials closer to participants and increase clinical trial enrollment rates (Agrawal et al., 2021; Rogers et al., 2022; Adesoye, Katz and Offodile, 2023).

This sentiment has spurred creative approaches, such as integration of retail pharmacies into the trial ecosystem (although one major player, CVS, has already left the business [Fierce Healthcare, 2023]).

Tailoring trial recommendations based on patient medication profiles and establishing connections during medication pickups—a strategy that proved fruitful during the pandemic—can drive efficiencies for sponsors and participants. Moreover, retail giants such as Walmart, with its widespread presence, offer an avenue to enhance trial visibility and extend outreach to a broader and more diverse patient base (see Chapter 6, Participant diversity drivers and infrastructure).

Engaging people who already use DHTs such as smartwatches could further streamline patient enrollment. An additional approach to improving data-gathering activities involves embedding trial-related information into contexts in which patients are already engaged, such as during blood donation. For example, researchers could add a simple targeted consent form into the existing forms, allowing patients to consent that a portion of their blood might be used for research. Such an approach could be introduced with minimal overhead. Experts further underscored the value of integrated electronic medical records. For instance, connecting clinical trials with diagnostic codes would allow clinicians to quickly suggest appropriate trials to qualifying patients, further increasing trial awareness and patient outreach.

The pandemic revealed that DCTs and DHTs can potentially include people who would otherwise remain excluded from trial participation, such as those from rural areas, from underprivileged regions, and with limited mobility or travel capabilities (Lee et al., 2021; Noonan and Simmons, 2021; Sedhai et al., 2021; Aitken, Connelly and Leamy, 2022). These technologies also represent opportunities for trials focused on rare diseases, in which localized patient clusters are typically absent (Moore et al., 2022; Rogers et al., 2022). Another novel opportunity involves including patients with severe conditions, such as severe Crohn's disease, who might be too ill to leave their homes and participate in traditional trials.

DCTs and DHTs are not universally appropriate solutions. They are often more suitable for later-phase trials (Osborne and Danheiser, 2023), for which safety profiles are better known, and for long-term studies and post-approval or post-market surveillance. Virtual patient visits might be inadequate for detecting certain symptoms and changes (Lee et al., 2021). The accuracy of remote measurements, whether self or device-reported, will require validation for each measurement and setting (Lee et al., 2021; Aitken, Connelly and Leamy, 2022; Osborne and Danheiser, 2023).

In some cases, DCTs might require higher upfront costs and investments in infrastructure, digital platforms, direct-to-patient medication delivery, and harmonization of protocols across local health centers (Aitken, Connelly and Leamy, 2022; Osborne and Danheiser, 2023). These costs might (or might not) be recouped through faster recruitment and higher retention rates as well as the reuse of software and tools for other trials. Another avenue for cost effectiveness is leveraging shared areas of interest across therapeutic domains. For instance, a therapeutic interest area such as nausea and vomiting holds relevance in gastroenterology and oncology. Identifying such cross-disciplinary points for reuse can justify investments in trial infrastructure and might increase the likelihood of success.

## Lessons Learned for decentralized clinical trials and digital health technologies

The accumulated expert interviews and literature outcomes of the use of DCTs and DHTs catalyzed by the COVID-19 pandemic underscore that DCTs and DHTs offer participant-centric approaches to clinical research and have the potential to reduce barriers to trial participation, enhance engagement, improve retention, and drive participants' satisfaction. These lessons apply to therapeutics, vaccines, and diagnostics in pandemic and non-pandemic (normal) contexts.

Telemedicine or virtual visits, in which therapy assessments and interventions are carried out online or at home, could reduce pandemic disruptions for many trials, not just pandemic product trials. Remote models can lower costs, focus on individual family needs, and support equal access to evidence-based quality. Achieving telemedicine advantages in non-pandemic settings will necessitate clarifications of and some updates to reimbursement and state-specific medical licensing regulations.

Decentralization supports the extension of trial participation to underserved populations, including rural, socioeconomically disadvantaged, and mobility-limited people, as well as patients with rare or severe diseases. At-home measurements can substitute for certain in-site visits, improving patient flexibility, generating RWE, and concurrently reducing costs and study coordination workload.

Fit-for-purpose uses of DCTs in "meeting people where they are" proved effective at various stages of a trial, ranging from recruiting, to consent, to data collection. Utilizing social media, pharmacist referrals, and/or community ambassador involvement are just some of the decentralized approaches that can support clinical trials. As such, DCTs and DHTs should be approached as tools to enhance the conduct of clinical trials, rather than distinct entities. For example, eIC processes, supplemented with visuals and videos, improves information retention and patient satisfaction, while also strictly adhering to the goals of informed consent processes for research.

With respect to any future clinical trials and for pandemic preparedness, it will be important to draw on experiences with the use of decentralized approaches and DHTs during the COVID-19 pandemic. These approaches and tools proved vital to keeping many trials going during the COVID-19 pandemic, but were widely viewed as "retrofits" and in many cases they were costly to incorporate into trial designs after-the-fact. Vitally, integration of situation-appropriate decentralized elements into clinical trials will result in building both the infrastructure and expertise needed for future pandemic resilience. As a corollary: solutions that "bolt on" DHTs and decentralized elements to existing trials will fail to take advantage of the full promise of these tools and learnings from the COVID-19 pandemic.

3 The Orphan Drug Act defines a rare disease as a disease or condition that affects fewer than 200,000 people in the United States.