# 3 Disruptions to clinical trials due to COVID-19

The COVID-19 pandemic disrupted operations for all clinical trial activities, from trial initiation and recruiting to execution, monitoring, and close-out. In many cases, these disruptions incentivized broad and swift adoption of innovative approaches.

Overall, in a direct year-over-year evaluation of clinical trials registered on ClinicalTrials.gov (https://www.recoverytrial.net/files/recovery-results_december-2022.png), 116 trials were suspended in 2019 compared with 769 trials in 2020 (Evidera, 2021). Among 300 global pharmaceutical companies, 75% of organizations paused site activation, and 50% paused recruitment at the beginning of the COVID-19 pandemic (Agrawal et al., 2020).

In addition, travel restrictions, global consumable shortages, supply chain disruptions, and social distancing guidelines were obstacles to conducting clinical research during the pandemic. The realities of social distancing made it difficult for patients to travel to trial sites and for trialists to monitor patients in person and perform otherwise normal trial-related tasks.

This chapter summarizes the types of interruptions experienced due to COVID-19 and their consequences to the clinical trial enterprise, and it briefly introduces the overarching themes that will be discussed in subsequent chapters.

## Types of interruptions

Studies have reported a variety of clinical trial disruptions from COVID-19 that affected ongoing trials that were in-progress or preparing to launch at the outset of the pandemic as well as the initiation of trials for COVID-19 vaccines and therapeutics. For example, clinical trials for cancer therapeutics and cardiovascular medical devices reported broad reductions in enrollment during the first year of the pandemic (Unger, Xiao, et al., 2021; Rymer et al., 2022). The cancer studies reported 23% average enrollment reductions over the first year of the COVID-19 pandemic (Unger, Xiao, et al., 2021), but in the cohort of cardiovascular device trials studied, over 80% were disrupted or not started because of mandated institutional shutdowns or patients' concerns related to interacting with the health system (Rymer et al., 2022). Other investigations suggest that COVID-19 led to delays in patients receiving chronic condition care, which subsequently affected clinical trial enrollment during the first year of the COVID-19 pandemic (Pretzel et al., 2022; Rose et al., 2022). Clinical staffing, fatigue, and shortages contributed to interrupted clinical trial operations. One expert from the National Institutes of Health (NIH) said that staff exhaustion during the COVID-19 pandemic resulted in the organization forcing employees to take a rest from the office and sending them home.

Many clinical trialists interviewed discussed how clinical trials were halted or shifted because of the lack of resources during the early months of the COVID-19 pandemic and the overall lack of volunteers. At the same time, experts observed that resources from ongoing trials—in particular, trial staffing and some reviewers—were shifted to COVID-19-related clinical trials. These and other factors led to a roughly 10% absolute decrease in clinical trial starts in 2020 relative to 2019 and an even greater decline compared with the steady year-over-year growth trendline observed in the years leading up to the COVID-19 pandemic (Lasch et al., 2022; IQVIA, 2023).

Responding to the impacts of the COVID-19 pandemic on participant and staff safety, trial operations, and data quality, the U.S. Food and Drug Administration (FDA) issued a guidance document in March 2020 (updated August 2021) (U.S. FDA Conduct, 2021) recommending that sponsors consider delaying initiation of new trials and pausing or slowing enrollment in ongoing trials. In 2021, clinical trial starts surged again as many of the previous year's delayed trials launched belatedly (Lasch et al., 2022; IQVIA, 2023).

The literature and expert interviews noted that trials early in the recruitment phase or those unable to pivot to virtual patient and site visits were among the most affected (Rymer et al., 2022). In such instances, decentralized trial techniques were not feasible from a practical, financial, information technology (IT), or staff resourcing perspective. For example, a participant’s physical presence might be necessary in cases such as those involving special patient populations or trials with complex interventions (e.g., cell therapies).

The literature also, however, highlighted examples of trials that were able to continue successfully by reducing in-person requirements. One primary-care-based diuretic point-of-care pragmatic trial that pivoted to remote follow-up sessions actually increased recruitment compared with pre-pandemic levels (Leatherman et al., 2023), and an in-hospital trial for acute stroke that used similar strategies was able to maintain participant diversity and patient follow-up levels (Yamal et al., 2021). Similarly, other trials in dementia and cancer obtained participant information by phone instead of in-person during this period while maintaining other pre-pandemic clinical trial management practices (Flores et al., 2021; Heintz, Clouqueur, and Puopolo, 2021; Park et al., 2022). An FDA official interviewed for this report emphasized that more resilient studies were more likely to rely on approaches such as electronically consenting patients, performing blood draws close to home, and conducting remote trial monitoring visits whenever possible (see Chapter 4, Decentralized clinical trials and digital health technologies).

Mitigation activities in clinical trial operations during the COVID-19 pandemic period increased costs, as many experts reported (though these are not yet well quantified at scale in the published literature), which might have affected trial success rates. Expert interviewees and the literature listed costs associated with additional resources needed to ensure that trial activities could continue safely (e.g., additional personal protective equipment), implement previously unplanned adoption and employment of decentralized approaches, and deploy digital health technologies (DHTs). In some cases, these activities rapidly drained trial budgets. Many conventional participant recruitment and retention channels were shuttered during the COVID-19 pandemic, forcing trialists, research organizations, and sponsors to pivot and amplifying the impact of initial disruptions.

One expert we interviewed further highlighted "unseen" challenges for specific clinical trial participant populations, sharing the anecdote of a working single mother whose child care closures compromised her availability to continue participating in a trial. Although widespread child care closures were specific to the COVID-19 pandemic, this example highlights how existing barriers and challenges to clinical trial participation were exacerbated by the institutional decisions taken during the COVID-19 pandemic. Similarly, experts noted that existing structural and socioeconomic barriers to trial participation such as participants' physical disabilities and/or dependency on public transportation are likely to become even stronger hindrances to people's ability to participate in clinical research during a public health emergency (see Chapter 6, Participant diversity drivers and infrastructure).

Clinical trials involving therapies for COVID-19 encountered a unique set of disruptions, including competition with other COVID-19 therapeutic trials for participants, contracting delays, and slow institutional review board (IRB) and regulatory protocol reviews from thinly stretched agencies (Goossens et al., 2022). FDA worked to help mitigate clinical trial interruptions early in the pandemic by rapidly issuing guidance documents on how to safely conduct trials (Turner, 2020) and increasing its consultations with sponsors. Experts broadly cited these guidance documents as beneficial and helpful as the basis for understanding how to best modify trial approaches when appropriate (see Chapter 8, Regulatory trial oversight and evaluation).