# 2 Methods

Over six months beginning in March 2023, an independent research team at Co-Bio Consulting, at the direction of the Office of the Assistant Secretary for Planning and Evaluation (ASPE), conducted a multiphase project designed to understand how the COVID-19 pandemic transformed the clinical trial enterprise. The team's qualitative research consisted of a literature review, interviews with high-level subject matter experts, and synthesis. The Co-Bio Consulting team prepared the report under contract with Mathematica with financial support and feedback from HHS. The Co-Bio Consulting team retained full editorial responsibility and any remaining errors are their own. The work focused on clinical trial developments, lessons learned, and forward-looking opportunities for U.S. policymakers.

Informed by a detailed literature review conducted in spring 2023,^2^ the research team identified a set of themes that capture core areas of lessons learned from clinical trials during the COVID-19 pandemic. This document includes insights from this work, which was constructed as an overview of (primarily peer reviewed) published expert knowledge accumulated over the 38 months after the COVID-19 pandemic began.

While synthesizing the literature, the research team also developed a set of interview guides to use as qualitative survey instruments in a diversified set of interviews with people who had high-level experience and expertise in each of the following five areas: (1) clinical trial design (in particular, statistical innovation in clinical trials), (2) clinical trial operations, (3) decentralized clinical trials and digital health technologies in clinical trials, (4) clinical trial diversity, and (5) regulatory oversight and evaluation of clinical trials.

The goal of the expert interviews was to fill in gaps and augment the findings from the targeted literature scan. As such, the five interview guides were designed to elicit information on the lessons learned in the conduct of clinical trials and recommended strategies or practices that likely provide the most benefit (e.g., reduce costs or time or increase diversity) to the clinical trial enterprise. The guides were also meant to help gather information on the types of products for which these lessons learned are likely to be most applicable going forward.

All interview guides were approved by Health Media Lab IRB on May 22, 2023. The research team conducted all interviews via Zoom.

Experts were identified according to their experience with clinical trials during the COVID-19 pandemic, with multiple experts representing each major regulated COVID-19 product type (vaccines, drugs, and devices). The team identified interviewees via the literature review and through the principal investigators’ experience and network. Although the team interviewed each expert using only one of the interview guides, several had expertise in more than one product category. Among the final set of interviewees, 10 had experience with vaccine trials, 12 with therapeutic trials, and seven with diagnostic/device trials). In total, the team interviewed 24 experts, with each of the unique interview guides used for no more than seven experts.

The findings have some limitations based on this project’s scope and design. The completion of this project from March to September 2023 means that the period of hindsight was only the 3 to 3.5 years after the onset of the COVID-19 pandemic. Further, the findings from the targeted literature review are necessarily limited to the top 20 pieces published by mid-2023 that met the keyword search phrases (see Appendix C), and many experts in the clinical trial enterprise might not publish the lessons they learned. The second phase of the study, the expert interviews, was designed to mitigate this potential source of bias by speaking with leaders in the field who were actively involved in clinical trial leadership during the pandemic. Although the expert interviews yielded new insights—a fact that is consistent with there still being gaps in the published literature—the number of such interviews conducted was limited to 24. Some latent insights were certainly missed because of the relatively small number of expert interviews. Further, because the interviews focused on senior organizational experts and principal investigators, the findings do not reflect insights from mid-level and operational clinical trial staff (e.g., clinical trial nurses, site monitors, phlebotomists, etc.) that were not shared with clinical trial leaders or shared by the interviewees.

2 To collect and aggregate information sources on the approach and strategies, including policy interventions, adopted in the clinical trial enterprise in response to the COVID-19 pandemic, the research team scanned the literature using a set of keywords selected with ASPE experts. The team performed keyword searches using LEXIS NEXIS, Google Scholar, and Google search engines from March to May 2023. The environmental scan was designed to capture lessons learned from clinical trials during COVID-19. For more detail on the literature scan and a full list of keywords, see Appendix C.