# 11 Conclusions

The academic and gray literature, as well as the expert participants interviewed for this research, provided examples and insights of the way COVID-19 impacted clinical trials and lessons learned around six key areas:

1. Decentralized clinical trials and digital health technologies
2. Platforms and statistical innovation in clinical trial design
3. Participant diversity drivers and infrastructure
4. RWE and the gap between clinical research and practice
5. Regulatory trial oversight and evaluation
6. General operational considerations for clinical trials

Overall, Americans dramatically benefited from the combined impact of clinical trial innovations during the COVID-19 pandemic. For example, innovative approaches helped bring COVID-19 vaccines to market in fewer than nine months rather than the usual nine years—a more than ten-fold improvement in speed in service of public health and millions of lives. Although resourcing levels and clinical appropriateness might prevent replication of these approaches across all medical products all the time, the COVID-19 clinical development experiences showed what could be possible and pointed toward what further improvements might be made.

Despite these benefits, little quantitative evidence is yet available on the impact of specific practices on clinical trial time, cost, diversity, and success. Future research could support quantification of that impact; two possible approaches that demonstrate initial feasibility are described in Appendix E.

## Key Lessons Learned

This report identifies a set of lessons learned for future policy and pandemic preparedness from each of these core thematic areas that includes the following recommendations for forward-looking policy:

1. Pandemic disruptions in clinical trials can be mitigated through designed resilience and pre-planned rapid response. Most ongoing and pre-launch trials were interrupted to some extent by the onset of the COVID-19 pandemic, but those using decentralized approaches were more resilient. Mitigating future clinical research disruptions may require combining contingency planning and rapid response.
2. DCTs and DHTs can expand participation and reach of clinical research. DCTs and DHTs allow clinical researchers to "meet people where they are" by offering participant-centric approaches to clinical research that enable (more) remote participation, extending clinical research sites to community and even home settings. This can prove particularly impactful for enrolling underserved populations. DCTs and DHTs should be approached as tools to enhance the conduct of clinical trials, rather than distinct entities. And while DHTs often have advantages, for some, clarifications and reforms regarding reimbursement and state-specific medical licensing regulations may be needed for non-emergency use in clinical research.
3. Platform trials and innovative statistical trial designs were highly effective in generating actionable evidence during the pandemic and have potential to streamline development more broadly. Platform trials and adaptive trials were a small portion of COVID-19 clinical trials, but they proved effective in generating actionable evidence for COVID-19 candidate therapeutics. Yet their speed and efficiency varied widely across platform types. Infrastructure differences, from governance to technical, appear to be important contributing factors to this variance. But sponsors perceive risks in adopting appropriate innovative designs. Regulatory guidance documents may partially address sponsor concerns, but commercial and operational risks will likely remain.
4. Clinical trials conducted during the COVID-19 pandemic provide lessons for improving participant diversity in clinical research. Innovative strategies for recruitment, such as social media, text messaging, and engaging community leaders proved successful in recruiting historically underrepresented populations. Explicitly including recruiting diversity into clinical trial plans is becoming a recognized best practice.
5. The United States benefited from real-world data and RWE but struggled to create its own. Highly fragmented medical data and IT systems combined with a lack of embedded research capabilities in clinical care made the United States dependent on others (the United Kingdom and Israel, among others) to identify effective clinical practices and candidate therapies during the COVID-19 pandemic.
6. Regulatory leadership proved critical to COVID-19 clinical trial efforts. Rapid issuance of clear clinical development guidance documents for each product type can galvanize researchers to pursue impactful product development, creatively and quickly. From adaptive trial designs to mitigating recruitment barriers to streamlining decision making, regulators showed that thoughtful crisis risk management can advance technical and organizational innovations by product sponsors that deliver outcomes previously believed impossible. However, heroic work can meet emergency needs but cannot become a new normal.

Incorporating and institutionalizing the lessons learned from clinical research during the COVID-19 pandemic requires a multi-modal and integrated approach to updating standard practices in clinical research going forward. Fully incorporating lessons learned will require more than institutional memory, reports, and playbooks. Process improvements (such as regular and increasing use of centralized and streamlined IRB processes) must be exercised, and capabilities need to be kept up to date or even newly created (such as clinical trial platforms and patient recruitment tools). This might be best accomplished not only by ensuring future pandemic readiness but also by actively encouraging the ongoing use of the best-practice innovations in ongoing non-pandemic clinical development whenever appropriate. Making some aspects of the changes adopted during the COVID-19 pandemic part of standard practice can increase the efficiency and impact of the clinical trial enterprise while simultaneously buffering the system against future disruptions.