# 10 Testing the lessons learned: areas for future analysis

The literature review and expert experiences presented above are particularly well suited for documenting experiential and qualitative lessons learned. Future work could quantitatively explore some of the themes in this report at scale and potentially test hypotheses suggested by the findings. Examples include the following:

- Examining use and impact of DHTs in registered clinical trials (in particular, by leveraging ClinicalTrials.gov) such as in the example presented in Part I of Appendix E.
- Documenting trends in clinical trial participant diversity—for both COVID-19 products (e.g., vaccines and therapeutics) and non-COVID-19-related products (e.g., oncology therapies). Part II of Appendix E presents an example of how an algorithmic approach could support such an analysis at a larger scale. The results would support efforts to improve representativeness of clinical trials, improving confidence in their generalizability and reducing resistance among underrepresented populations to use the medical products.
- Exploring clinical trial site diversity among geographies (states; urban/rural) and settings (home, pharmacies, mobile clinic, community clinic/practice, hospital, etc.) and the impact on clinical trial speed, cost and diversity.
- Quantifying the time, cost, and diversity impacts of individual (or combinations of) clinical trial innovations, such as decentralized or DHT trial elements (e.g., text messaging, social media outreach, self- and home-monitoring), platform trials, adaptive trial designs, and community outreach efforts. Many of these approaches have not been rigorously evaluated by direct comparisons within or across trials or otherwise. NIH's All of Us Research Program, which includes decentralized and centralized recruitment cohorts, could provide an opportunity for such research.
- Testing intersectional theme synergies to differentiate relative contributing factors and their mutual reinforcement (synergy effects). For example, it might be valuable to explore the extent to which the use of decentralized approaches or specific tools such as text messaging or social media outreach affect the length of clinical trials or the likelihood that such trials fully enroll. Similarly, one could explore how the use of DHTs (or specific types of DHTs) correlates with trial diversity and representativeness.
- Studying regulatory change propagation times to understand the lags and impact of regulatory changes through the clinical trial enterprise. Because trials often take years, and trialist risk-avoidance reduces new method adoption, the time required to realize new regulatory opportunities for DCTs, DHTs, adaptive designs, and so on could be quite lengthy. There has been little tracking of these adoption times or research regarding what factors or incentives affect those times.

Testing each of these elements would entail significant original research cost and time. Prioritizing only the most critical for field testing will be necessary, but some elements or topics can be explored using existing data sources. Appendix E presents preliminary data from two early feasibility analyses in greater detail.