# 1 Report summary

The COVID-19 pandemic disrupted clinical trials in early 2020 and created an urgent need for new diagnostics, therapeutics, and vaccines. The clinical trial community's response propelled greater use of new and existing tools, such as community outreach to increase the diversity of trial participants; decentralized patient monitoring and recruitment; innovative trial designs; real-world evidence (RWE) from point-of-care research; and collaboration between multiple federal agencies, industry, and academia.

This report summarizes research to reveal the impacts of the COVID-19 pandemic on the clinical trial enterprise, the innovations it engendered, and the implications for future pandemic preparedness as well as how to improve practices for all clinical trials.^1^

The research entailed a targeted literature review followed by interviews with experts from within the clinical trial enterprise. The research describes disruptions to clinical trials due to COVID-19 and specific impacts and lessons learned in six broad areas:

1. Decentralized clinical trials and digital health technologies
2. Platforms and statistical innovation in clinical trial design
3. Participant diversity drivers and infrastructure
4. RWE and the gap between clinical research and practice
5. Regulatory trial oversight and evaluation
6. General operational considerations

The COVID-19 pandemic led to widespread disruption of clinical trials and simultaneously necessitated the urgent conduct of trials for COVID-19 diagnostics, therapeutics, and vaccines. Most ongoing and pre-launch trials were interrupted to some extent by the COVID-19 pandemic, but those trials that allowed for research to take place in local clinics or even in participants' homes were more resilient. Chapter 2 explains the methods used to produce this report, and Chapter 3 summarizes the types of disruptions to clinical trials during the COVID-19 pandemic. Subsequent chapters explore specific ways in which clinical trials conducted during the COVID-19 pandemic mitigated these disruptions as well as the lessons learned for both pandemic-era and everyday clinical trials.

Chapter 4 describes the role of decentralized clinical trials (DCTs) and digital health technologies (DHTs) during the COVID-19 pandemic. DCTs and DHTs offer participant-centric approaches to clinical research that enable (more) remote participation, extending clinical research sites to community and even home settings. These approaches and tools can prove particularly impactful for enrolling underserved populations, including rural, socioeconomically disadvantaged, and mobility-limited people, as well as patients with rare or severe diseases. Beyond enrollment, COVID-19-era clinical trials demonstrated that appropriately decentralizing activities to community clinics can reduce participant barriers during treatment and monitoring. However, DCTs and DHTs are not necessarily appropriate or feasible for all trials, and clarifications and reforms regarding reimbursement and state-specific medical licensing regulations for activities such as telemedicine might be necessary for non-emergency use in clinical research.

Chapter 5 describes the use of platforms and statistical innovation in clinical trial design during the COVID-19 pandemic. Platform trials, in which multiple products are evaluated simultaneously under a master protocol (among other features), proved effective at generating action-oriented evidence for COVID-19 candidate therapeutics. The variations among platforms showed that their use is not, however, a guarantee of speed and efficiency. Rather, platform design, governance, and technical infrastructure all appeared fundamental to platform performance. Bayesian adaptive trial designs in some cases generated comparable results faster and with fewer enrolled participants than frequentist designs. Although these strategies proved particularly effective during the COVID-19 pandemic, broader uptake of these innovative approaches may speed development and reduce costs for trials conducted outside of a pandemic scenario.

Chapter 6 discusses the impacts that COVID-19 disruptions and mitigation strategies had on the diversity of clinical trial participation. Historically, clinical trial participants have imperfectly represented the patient populations who are likely to use the medical products being studied. For COVID-19 vaccine and therapeutic trials, clinical trialists sought broad participation in COVID-19 vaccine and therapeutic trials using a wide range of non-traditional recruitment strategies, including social media, partnering with retail pharmacies, and engaging community leaders. The COVID-19 pandemic demonstrated that increased diversity can be achieved by explicitly planning diversity recruitment activities; without broader implementation of these approaches, however, diversity gaps will persist in future clinical trials.

Chapter 7 describes RWE and the gap between clinical research and practice. Highly fragmented medical data and information technology systems combined with a lack of embedded research capabilities in clinical care limited the use of RWE to identify effective clinical practices and candidate therapies early in the COVID-19 pandemic. As a result, the United States had to depend on evidence from other countries (the United Kingdom and Israel, among others) with more unified medical record systems, detailed public health surveillance, and embedded clinical research capabilities in their clinical care. Reducing health data fragmentation while simultaneously allowing access by researchers could improve clinical trials during normal contexts and prove critical to rapid response during pandemics.

Chapter 8 describes regulatory trial oversight and evaluation. Federal leadership, through coordination among government agencies and private organizations, proved critical for mitigating immediate impacts and galvanizing action for all trials during the period. The timely publication of clear guidance documents for the performance targets of COVID-19 vaccines especially helped the trials for those products. Clinical trial sponsors and their study sites described rapid and frequent guidance documents from the U.S. Food and Drug Administration as having enabled rapid restarts of existing trials and initiation of COVID-19 product trials. All future clinical trials can apply these regulatory lessons of proactive guidance and policy communication, mutual education for collaborative innovation, and streamlining protocols to processes.

Finally, Chapter 9 presents additional operational approaches that were taken to streamline clinical trials during COVID-19. These include strategies to reduce start-up time, including simplified contracting, innovative recruitment approaches to both speed and diversify participation, and integrated data systems that expedited data collection, processing, and database lock. Many of these approaches could be implemented more broadly after the COVID-19 pandemic to accelerate clinical development for a wide range of product types. More generally, future clinical trial contingency planning should be robust, especially regarding personnel issues such as personal health protection, absentee rates from diversion or illness, and wellness management and exhaustion avoidance.

Although the literature and expert interviews documented a wide range of disruptions, mitigation strategies, and innovations in the clinical trial space during COVID-19, there is still very little known about the quantitative impacts on clinical trial costs, trial success, or other factors. In Chapter 10, the report concludes with areas for future quantitative research to understand the impact of the approaches taken during the COVID-19 pandemic.

1 For readability, this report summary does not include citations. Instead, these cites appear in each of the detailed themed sections, with corresponding references in the bibliography.