# 16 APPENDIX E: Testing the lessons learned: feasibility demonstrations

## Part I: analyzing the use of DHTs in registered clinical trials

As described above, DHTs received increased regulatory guidance and active use in clinical trials during the COVID-19 pandemic (U.S. FDA DHT, 2023). An early investigation of DHTs in clinical trials before and after the onset of the COVID-19 pandemic considered trials that launched in the 10 months prior to the COVID-19 pandemic onset (May 2019–February 2020) and compared them with trials launched during the 10 months following the acute lockdown phase of the COVID-19 pandemic (May 2020–February 2021) (Marra et al., 2021). The study (Marra et al., 2021) found that the use of "connected digital products" (a category which was defined nearly identically to FDA's definition of DHTs) increased by only 1.65 percentage points from the earlier to the later period—from 14.19% of all trials initiated in the 10 months prior to the COVID-19 pandemic onset to 15.84% of those started in the 10 months following (p<0.01). Notably, the authors found that the increase was observed "primarily in observational studies and non-industry funded trials and was driven entirely by connected digital product usage in trials for COVID-19," raising questions as to the lasting impact of DHTs in clinical trials.

It is important to examine longer-term trends, as previous research has demonstrated DHTs grew at a ∼34% cumulative annual growth rate in the years from 2000 through 2018 (Marra et al., 2021). The study (Marra et al., 2021) considers only a brief period before and after the COVID-19 pandemic onset, which did not allow the study design to capture longer-term trends in the growth of DHTs in clinical trials. To address these two shortcomings, the authors piloted an exercise in which a significantly longer period of time—both before and after the COVID-19 pandemic onset—could be considered in detail. Below, the authors present two example analyses in which the use of DHTs are considered in registered clinical trials included in ClinicalTrials.gov from March of 2017 through the end of March of 2023.

In the first exhibit, aggregated trials are represented by the solid gray line: interventional (light blue), observational (royal blue), non-industry funded (dark pink), and industry funded trials (light pink), are also represented as separate lines. The period immediately after the COVID-19 pandemic onset (March-June 2020) is considered the "disruption" period, while the two-year period beginning in July 2020 is considered the "adaptation" period. The period thereafter, which followed the formal end of the public health emergency is labeled here as the "new normal" period.

Exhibit 1 Proportion of clinical trials using DHT by month

A time series graph showing that non-industry funded trials use DHTs more than industry funded trials; that interventional trials use DHTs more than observational trials.

The second exhibit presents bar charts showing the same breakdowns by study sponsor type, where overall average shares of trials using DHTs are presented during the same time periods: the pre-pandemic (PP) period, the disruption (DR) period, the adaptation (AD) period, and the new normal (NN) period. In this exhibit, COVID-19 trials are in shades of orange, while non-COVID-19 trials are in shades of green.

Exhibit 2 Proportion of clinical trials using DHT by COVID-19 pandemic period: pre-period; disruption period, adaptation period; new normal period

A grouped vertical column chart showing the number of clinical trials started that use DHTs pre- or post-pandemic by type of trial (all, interventional, observational, industry funded, non-industry funded) and by COVID-19 product or non-COVID-19 products. COVID-19 product trials used DHT more than non-COVID-19 products. Interventional and non-industry funded trials show ever increasing use of DHTs over time. Observational and industry funded trials use DHTs less in the final ‘new normal’ period compared to the ‘disruption’ period.

Discussion of DHT analysis results. Sponsor reported DHT use saw an increase in the COVD-19 'adaptation' period on average and across most sponsor types. While too early for final conclusions, it appears that a leveling of DHT use in the "new normal" period may be occurring.

Industry reported DHT use remains approximately half that seen in non-industry sponsored trials. Industry sponsored trials also appear to have declined slightly from its peaks while non-industry use has sustained or even slightly increased DHT use in the "new normal" phase.

ClinicalTrials.gov data does not currently support analysis of potential causes for the "new normal" plateau. It may be that DHT use is now considered so normal that sponsors feel no need to call it out in their ClinicalTrials.gov reporting since the system does not contain dedicated fields for reporting DHT use. Or it may be that trialists view DHTs only as extraordinary measures for a crisis not applicable for ordinary times. Reasons may include the complexity, cost, planning effort of using DHTs or the belief that the risk of trial initiation delay outweighs potential benefits of DHT use. The momentum of traditional trial processes and in-place supporting capability from staff to technology might also contribute to the stalled, and low-level, adoption of DHTs. Exploring such themes will likely require use of alternative methods (such as surveys), identification of alternative data sources, enhancement of ClinicalTrials.gov to formally collect DHT use data, or a combination of these or other approaches.

## Part II: analyzing clinical trial diversity reporting and representativeness at scale

The eligible treatment population (ETP) to receive a drug or vaccine may differ from the clinical trial participants by demographic and non-demographic characteristics such as comorbidities, condition severity, pregnancy, and others. The FDA has encouraged clinical trialists to broaden the diversity of clinical trials to better match the most likely to be treated population (U.S. FDA Diversity, 2020).

The resistance exhibited by some populations that viewed themselves as underrepresented in the COVD-19 vaccine and therapy trials. Shearn and Krockow (2023) highlighted the importance of clinical trials representing the ETP. Quantitatively and systematically characterizing clinical trial diversity has not been done although some preliminary semi-quantitative scorecard analysis has been posted on medRxiv by the FDA (Fitzsimmons, Idris and Pemu, no date) and European pivotal trials have had some analysis (Smith, Botto and Getz, 2022). Quantifying U.S. clinical trial diversity would enable better projections of representativeness, provide increased accountability, and may lead to reduced public hesitancy for new treatments as diversity demonstrably improves.

Clinical trial publications nearly universally now report their demographic characteristics in a "Table 1” included in each article published in a medical journal abiding by International Committee of Medical Journal Editors (ICMJE) standards (ICJME, no date). Table 1 demographics included in clinical trial publications describe the trial population participant by age, biological sex, race/ethnicity, and occasionally other descriptors the trialists deem relevant. It is typically left to the reader to calculate and decide whether the trial is representative of the likely to be treated patient population.

The common inclusion of "Table 1" in clinical trial publications enables a computer scalable extraction process that when coupled with natural language processing tools can generate a raw data set for curation and subsequent analysis of clinical trial participant diversity.

Table E1 below demonstrates the feasibility of such an approach on a test set of PubMed COVID-19 vaccine clinical trial articles. Structured "Table 1" demographic data were included in most papers (44 of 48; 92%) describing COVID-19 vaccine trials indexed in PubMed and reported in ClinicalTrials.gov. ClinicalTrials.gov registration is required for trials: included in FDA review applications; in select other FDA oversight circumstances; that are funded by the NIH; or that will be published in an ICMJE compliant journal (ICJME, no date; U.S. FDA Role, 2023).

Two thirds of demographic tables included in the pilot exercise presented contained race or ethnicity data at any level (30 of 44; 68%). The pilot exercise successfully extracted nearly all the demographic tables with race or ethnicity data (29 of 30; 97%). Scaling this study approach to all COVID-19 pandemic era trials of interest is feasible.

Table E1 COVID-19 vaccine trial articles with race or ethnicity

| n
PubMed Article having in Title: covid AND vaccine AND (safety OR efficacy OR immunogenicity) | 713
with Text Availability equal to “Free Full Text” | 615
with Article Type as “Clinical Trial” | 65
with a corresponding ClinicalTrials.gov NCT ID | 48
with a Table 1 | 44
that contains Race or Ethnicity | 30
and that is scrapable via R | 29

While biological sex reporting is highly standardized, age groupings have not been as standardized (especially for pediatric trials). In addition, only the largest race and ethnicity U.S. Census categories may be reported, as this example illustrates. Clinical trial utility for regulatory and clinical decision making, not merely systematic analysis, would be facilitated by a detailed clinical trial publication requirement.

### Example diversity representativeness report for a single trial

Walsh and colleagues (2020) published the results of a 195 adult participant, Phase 1 trial NCT04368728 (https://clinicaltrials.gov/ct2/show/NCT04368728) regarding the safety and immunogenicity of two RNA-based COVID-19 vaccine candidates. Due to racial differences in the types of human leukocyte antigens (HLA), which play a critical role in the immune system response to viruses, and declining immune systems in older adults, understanding population representativeness is important for projecting trial results to the general population. Hepatitis C treatments (Thio et al., 2001), transplant access (Pidala et al., 2013), and COVID-19 susceptibility, severity, and mortality (Deb et al., 2022) demonstrate this. Furthermore, eliminating poor vaccine candidates early eliminates large subsequent trials not just reducing cost but also reducing the competition for possibly scarce participants, research sites and clinical trialist staff as well as de-risking the portfolio of candidate products.

Table E2 Example “Table 1” race and ethnicity co-mingled reporting from COVID-19 vaccine trial NCT04368728 (https://clinicaltrials.gov/ct2/show/NCT04368728)

Race or Ethnicity | BNT162b1 | | BNT162b2 | | Total | % of Total
| 18–55 | 65–85 | 18–55 | 65–85
White (Non-Hispanic | 49 | 41 | 37 | 45 | 172 | 88.2%
Black | 2 | 1 | 3 | 0 | 6 | 3.1%
Asian | 7 | 2 | 3 | 0 | 12 | 6.2%
Hispanic | 2 | 1 | 2 | 0 | 5 | 2.6%
Total | | | | | 195 | 100.0%

In the reported Table 1 for the clinical trial, the trial had the 195 participants self-report their race and ethnicity but did not have them distinguish between their race and their ethnicity. The resulting admixture is summarized in Table E2 in which the 5 Hispanic ethnicity participants do not report a separate race. For the following analysis we assumed that they were white Hispanic recognizing the possible error that some or all may have been from other races.

Table E3 Example “Table 1” race and ethnicity characteristics from COVID-19 vaccine trial NCT04368728 (https://clinicaltrials.gov/ct2/show/NCT04368728)

Race | n
White | 177
Black or African American | 6
Asian | 12
American Indian/Alaskan Native | 0
Native Hawaiian or Other Pacific Islander | 0
Indigenous South American | 0
Total | 195
Ethnicity | n
Hispanic | 5
Non-Hispanic White | 172
Total | 177

Demographic comparisons to the eligible treatment population of U.S. adults suggests substantial underrepresentation of Black and Hispanic participants in the study (Table E3). The clinical trial either did not recruit members from two census race groups (American Native/Alaskan Native and Native Hawaiian or Other Pacific Islander), or the authors grouped them into the three reported race categories without describing the method of doing so.

Adding summary statistics for the estimated eligible treatment population demographics and their percentage difference from the realized trial population would enhance transparency of the representativeness of any given trial. This would facilitate discussion of the generalizability of the trial results. This report’s research team has piloted such an exercise (Table E4) which suggests that future research might feasibly explore diversity analysis at scale across large numbers of clinical trials.

Table: E4 Example race or ethnicity comparison for COVID-19 vaccine trial NCT04368728 (https://clinicaltrials.gov/ct2/show/NCT04368728) and the target treatment population of U.S. adult populations

Race or Ethnicity | Trial (%) | US ETP Population (% ≥18) | Direct Difference (pp) | Relative Difference (%)
White (non-Hispanic) | 88.2% | 53.3% | 34.9% | 65.4%
Black | 3.1% | 12.0% | −8.9% | −74.4%
Asian | 6.2% | 6.1% | 0.1% | 0.9%
Hispanic | 2.6% | 10.8% | −8.2% | −76.2%
American Indian/Alaska Native alone | | 1.1% | −1.1% | −100.0%
Native Hawaiian or Pacific Islander alone | | 0.2% | −0.2% | −100.0%
Other race alone | | 7.7% | −7.7% | −100.0%
Two or more races | | 8.8% | −8.8% | −100.0%

* US population from Census “2020 Census Illuminates Racial and Ethnic Composition of the Country” (Figure 5): https://www.census.gov/library/stories/2021/08/improved-race-ethnicity-measures-reveal-united-states-population-much-more-multiracial.html

pp: percentage points

Although this example describes only a single study, it suggests that a more systematic diversity survey, perhaps with sub-analyses by study phase and product type (vaccine, therapeutic, and diagnostic) could further describe the clinical trial representativeness of the anticipated eligible treatment population and inform the relative effort level that might be required to close any systematic gaps.

Exhibit 3 Under/over representativeness in an example COVID-19 clinical trial

A horizontal bar chart showing the under-representation or over-representation of racial groups in an example clinical trial. In this single trial, White participants were over greatly over-represented, Asian participants were represented approximately proportionately, Hispanic and Black participants were under-represented by 75% and reporting on all other racial categories was absent (100% under-represented).