# 15 Appendix D: FDA COVID-19 related guidance documents directly regarding clinical trials

Below is a list of the 21 guidance documents directly related to clinical trials compiled from the FDA current and archived webpages entitled "COVID-19-Related Guidance Documents for Industry, FDA Staff, and Other Stakeholders".

Title | Product Area | Date Posted
Policy for Certain REMS Requirements During the COVID-19 Public Health Emergency Guidance for Industry and Health Care Professionals (https://web.archive.org/web/20211225022840/http:/www.fda.gov/regulatory-information/search-fda-guidance-documents/policy-certain-rems-requirements-during-covid-19-public-health-emergency-guidance-industry-and) | Drugs, Biologics | 22-Mar-20
COVID-19 Public Health Emergency: General Considerations for Pre-IND Meeting Requests for COVID-19 Related Drugs and Biological Products (https://web.archive.org/web/20220122122016/https://www.fda.gov/regulatory-information/search-fda-guidance-documents/covid-19-public-health-emergency-general-considerations-pre-ind-meeting-requests-covid-19-related) | Drugs, Biologics | 11-May-20
Supplements for Approved Premarket Approval (PMA) or Humanitarian Device Exemption (HDE) Submissions During the Coronavirus Disease 2019 (COVID-19) Public Health Emergency (https://web.archive.org/web/20211225022840/http:/www.fda.gov/regulatory-information/search-fda-guidance-documents/supplements-approved-premarket-approval-pma-or-humanitarian-device-exemption-hde-submissions-during) | Biologics, Medical Devices | 21-May-20
Effects of the COVID-19 Public Health Emergency on Formal Meetings and User Fee Applications — Questions and Answers (https://web.archive.org/web/20211203221115/https://www.fda.gov/regulatory-information/search-fda-guidance-documents/effects-covid-19-public-health-emergency-formal-meetings-and-user-fee-applications-questions-and) | Drugs, Biologics | 26-May-20
Institutional Review Board (IRB) Review of Individual Patient Expanded Access Requests for Investigational Drugs and Biological Products During the COVID-19 Public Health Emergency (https://web.archive.org/web/20220117221343/https://www.fda.gov/regulatory-information/search-fda-guidance-documents/institutional-review-board-irb-review-individual-patient-expanded-access-requests-investigational) | Drugs, biologics | 2-Jun-20
Statistical Considerations for Clinical Trials During the COVID-19 Public Health Emergency Guidance for Industry (https://web.archive.org/web/20211203013744/https://www.fda.gov/regulatory-information/search-fda-guidance-documents/statistical-considerations-clinical-trials-during-covid-19-public-health-emergency-guidance-industry) | Drugs, Biologics, Animal & Veterinary, Medical Devices | 16-Jun-20
Development and Licensure of Vaccines to Prevent COVID-19 (https://web.archive.org/web/20211226045305/https://www.fda.gov/regulatory-information/search-fda-guidance-documents/development-and-licensure-vaccines-prevent-covid-19) | Biologics | 30-Jun-20
Assessing COVID-19-Related Symptoms in Outpatient Adult and Adolescent Subjects in Clinical Trials of Drugs and Biological Products for COVID-19 Prevention or Treatment (https://web.archive.org/web/20211225022840/http:/www.fda.gov/regulatory-information/search-fda-guidance-documents/assessing-covid-19-related-symptoms-outpatient-adult-and-adolescent-subjects-clinical-trials-drugs) | Drugs, Biologics | 14-Sep-20
Effects of the COVID-19 Public Health Emergency on Formal Meetings and User Fee Applications for Medical Devices - Questions and Answers (https://web.archive.org/web/20211125180216/https://www.fda.gov/regulatory-information/search-fda-guidance-documents/effects-covid-19-public-health-emergency-formal-meetings-and-user-fee-applications-medical-devices) | Biologics, Medical Devices | 22-Dec-20
COVID-19: Potency Assay Considerations for Monoclonal Antibodies and Other Therapeutic Proteins Targeting SARS-CoV-2 Infectivity (https://web.archive.org/web/20211225022840/http:/www.fda.gov/regulatory-information/search-fda-guidance-documents/covid-19-potency-assay-considerations-monoclonal-antibodies-and-other-therapeutic-proteins-targeting) | Drugs | 13-Jan-21
Protecting Participants in Bioequivalence Studies for Abbreviated New Drug Applications During the COVID-19 Public Health Emergency (https://web.archive.org/web/20220122135739/https://www.fda.gov/regulatory-information/search-fda-guidance-documents/protecting-participants-bioequivalence-studies-abbreviated-new-drug-applications-during-covid-19) | Drugs | 15-Jan-21
Investigational COVID-19 Convalescent Plasma (https://web.archive.org/web/20211225022840/http:/www.fda.gov/regulatory-information/search-fda-guidance-documents/investigational-covid-19-convalescent-plasma) | Biologics | 11-Feb-21
Policy for Evaluating Impact of Viral Mutations on COVID-19 Tests (https://web.archive.org/web/20211225022840/http:/www.fda.gov/regulatory-information/search-fda-guidance-documents/policy-evaluating-impact-viral-mutations-covid-19-tests) | Medical Devices | 22-Feb-21
Development of Monoclonal Antibody Products Targeting SARS-CoV-2, Including Addressing the Impact of Emerging Variants, During the COVID 19 Public Health Emergency (https://web.archive.org/web/20211225022840/http:/www.fda.gov/regulatory-information/search-fda-guidance-documents/development-monoclonal-antibody-products-targeting-sars-cov-2-including-addressing-impact-emerging) | Drugs | 22-Feb-21
COVID-19: Developing Drugs and Biological Products for Treatment or Prevention (Updated) (https://web.archive.org/web/20220111182222/https://www.fda.gov/regulatory-information/search-fda-guidance-documents/covid-19-developing-drugs-and-biological-products-treatment-or-prevention) | Drugs, Biologics | 22-Feb-21
COVID-19: Master Protocols Evaluating Drugs and Biological Products for Treatment or Prevention (https://web.archive.org/web/20211225022840/http:/www.fda.gov/regulatory-information/search-fda-guidance-documents/covid-19-master-protocols-evaluating-drugs-and-biological-products-treatment-or-prevention) | Drugs, Biologics | 17-May-21
Emergency Use Authorization for Vaccines to Prevent COVID-19 (Updated) (https://web.archive.org/web/20211225022840/http:/www.fda.gov/regulatory-information/search-fda-guidance-documents/emergency-use-authorization-vaccines-prevent-covid-19) | Biologics | 25-May-21
FDA Guidance on Conduct of Clinical Trials of Medical Products During the COVID-19 Public Health Emergency (Updated August 30, 2021) (https://web.archive.org/web/20211225022840/http:/www.fda.gov/regulatory-information/search-fda-guidance-documents/fda-guidance-conduct-clinical-trials-medical-products-during-covid-19-public-health-emergency) | Drugs, Biologics, Medical Devices | 30-Aug-21
Development of Abbreviated New Drug Applications During the COVID-19 Pandemic – Questions and Answers Guidance for Industry (https://web.archive.org/web/20211119022551/https://www.fda.gov/regulatory-information/search-fda-guidance-documents/development-abbreviated-new-drug-applications-during-covid-19-pandemic-questions-and-answers) | Drugs | 8-Sep-21
Policy for Coronavirus Disease-2019 Tests During the Public Health Emergency (Revised) (https://web.archive.org/web/20211226224659/https://www.fda.gov/regulatory-information/search-fda-guidance-documents/policy-coronavirus-disease-2019-tests-during-public-health-emergency-revised) | Medical Devices | 15-Nov-21
Enforcement Policy for Non-Invasive Remote Monitoring Devices Used to Support Patient Monitoring During the Coronavirus Disease-2019 (COVID-19) Public Health Emergency (Revised) (https://web.archive.org/web/20220120204506/https://www.fda.gov/regulatory-information/search-fda-guidance-documents/enforcement-policy-non-invasive-remote-monitoring-devices-used-support-patient-monitoring-during) | Medical Devices | 28-Oct-20