# 14 Appendix C: Search terms for environmental scan

| Search Phrase
1 | “clinical trial” + “COVID”
2 | “adaptive trial” + “COVID”
3 | “platform trial” + “COVID”
4 | “diagnostic” + “COVID”
5 | “vaccine” + “trial” + “COVID”
6 | “clinical trial” + “COVID” + “diversity”
7 | “clinical trial” + “COVID” + “innovation”
8 | “clinical trial” + “COVID” + “delay”
9 | “clinical trial” + “COVID” + “interrupt”
10 | “clinical trial” + “COVID” + “wearables”
11 | “virtual clinical trial” + “COVID”
12 | “decentralized clinical trial” + “COVID”
13 | “virtual clinical trial” + “COVID”
14 | “clinical trial” + “COVID” + “telemedicine”
15 | “covid” + “trial” + “lessons”
16 | “COVID” + “clinical development” + “trends”
17 | “COVID” + “clinical development” + “evolution”
18 | “COVID” + “trial” + “platforms”
19 | “COVID” + “trial” + “decentralization”
20 | “COVID” + “trial” + “costs”
21 | “COVID-19” + “vaccine” + “candidates” + “trial designs”
22 | “Applying” + “COVID” + “trial” + “innovations”
23 | “COVID” + “trial” + “acceleration”
24 | “COVID” + “diagnostic” + “development” + “lessons”
25 | “COVID” + “Therapeutics” + “Trials” + “Innovation”
25 | “COVID” + “Therapeutics” + “Trials” + “Lessons”
26 | “COVID” + “RWE” + “Trials” + “Innovation”
27 | “COVID” + “Real-world evidence” + “Trials” + “Innovation”
27 | “COVID” + “RWE” + “Trials” + “lessons”
28 | “COVID” + “Telemedicine” + “Trials” + “Innovation”
29 | “COVID” + “Telehealth” + “Trials” + “Innovation”
30 | “COVID” + “trial” + “trends”
31 | “COVID” + “trial” + “evolution”
31 | “COVID” + “clinical development” + “lessons”