# 13 Appendix B: Acronyms

ASPE: Office of the Assistant Secretary for Planning and Evaluation
CDC: Centers for Disease Control and Prevention
DCT: decentralized clinical trial
DHT: digital health technology
eIC: electronic informed consent
EHR: electronic health record
ETP: eligible treatment population
FDA: U.S. Food and Drug Administration
HHS: U.S. Department Health and Human Services
ICMJE: International Committee of Medical Journal Editors
IT: information technology
IRB: institutional review board
NIH: National Institutes of Health
RCT: randomized controlled trial
RWE: real-world evidence