# 12 Appendix A: Definitions

[underlined: Adaptive trial:] The FDA defines an adaptive design as one that allows for prospectively planned modifications to one or more aspects of the design based on accumulating data from subjects in the trial. Adaptive designs can make conventional clinical trials more flexible by employing results generated in the trial to amend the trial's course in accordance with pre-specified parameters. Such adaptations to the trial's course may include stopping an arm early for safety or due to futility, terminating recruitment to an arm prematurely in the event of efficacy, or amendment of target sample size or allocation ratios.

Adaptive study designs often use Bayesian analysis (see below) to facilitate an agile trial process, allowing for the rapid evaluation of multiple hypotheses across varying indications and therapies, leading to more efficient futility analyses, identification of promising candidates, and the dynamic shifting of patient recruitment to accelerate evidence for those promising candidates.

Adaptive trials may evaluate single agents, or multiple agents in parallel. For example, single agent designs involve one candidate (simplifying the assumptions or methods that can be used), while multiple agent designs assess multiple therapies where the toxicity curve or other properties may not be well understood, defined, or both.

[underlined: Bayesian Analysis:] Bayesian statistics is an approach for learning from evidence as it accumulates. In traditional (frequentist) clinical trials, statistical methods may use information from previous studies only at the design stage. Then, at the data analysis stage, the information from those previous studies is considered as a complement to, but not part of, the formal analysis. In contrast, the Bayesian approach uses Bayes' Theorem to formally combine prior information with current information on a quantity of interest. The Bayesian idea is to consider the prior information and the trial results as part of a continual data stream, in which inferences are being updated each time new data become available. Bayesian analysis allows trialists to combine prior data about a given parameter with evidence from information contained in a new sample to guide the statistical inference process. A probability distribution for the parameter of interest must be specified from the outset. Bayesian frameworks can be applied to all models, including but not limited to exponential, logistic regression, proportional hazard Weibull, survival regression, and participant randomization.

[underlined: Decentralized clinical trials (DCTs):] The FDA defines DCTs as clinical trials where some or all of the trial-related activities occur at locations other than traditional clinical trial sites. In full DCTs, all activities take place at locations other than traditional trial sites. These trial-related activities may take place at the homes of trial participants or in local health care facilities that are convenient for trial participants. In hybrid DCTs, some trial activities involve in-person visits by trial participants to traditional clinical trial sites, and other activities are conducted at locations other than traditional clinical trial sites, such as participants' homes.

[underlined: Digital health technologies (DHTs):] Includes a wide range of products that are used in healthcare settings or have a medical purpose. FDA notes that these include electronic sensors, computing platforms and information technology, which, in turn, provide new opportunities to obtain clinical trial data directly from patients. Portable DHTs that may be worn, implanted, ingested, or placed in the environment allow real-time collection of data from trial participants in their homes or at locations remote from clinical trial sites. The FDA definition of DHTs includes Software as a Medical Device (SaMD), Mobile Medical Applications (Mobile Apps), Wearable Devices or Telemedicine and Telehealth Platforms.

[underlined: eIC:] Electronic informed consent (often also referred to as "eConsent") involves electronic systems and processes that may employ (multiple) digital or electronic media sources to obtain informed consent for both HHS-regulated human subject research and FDA-regulated clinical investigations of medical products. This includes human drug and biological products, medical devices, and combinations thereof. FDA's requirements for electronic records/electronic signatures, informed consent, and IRBs are set forth in 21 CFR parts 11, 50, and 56, respectively. HHS requirements regarding the protection of human subjects are set forth in 45 CFR part 46. The information presented to the subject, processes used for obtaining informed consent, and documentation of the eIC must meet the requirements of these and other applicable regulations.

[underlined: Master protocol:] FDA notes increased interest in expediting late-stage product development by developing trial designs that test multiple drugs and/or multiple subpopulations in parallel under a single protocol without a need to develop new protocols for every trial. The term master protocol is often used to describe trials with a variety of designs including umbrella, basket, or platform trials.

A master protocol typically has multiple sub-studies, which may have different objectives and involve coordinated efforts to evaluate one or more medical products in one or more disease subtypes within a broader study structure.

[underlined: Platform trial:] Platform trials are open ended trials that occur under master protocols (see below), facilitating the addition, evaluation, and elimination of trial arms/candidates without specifying timing parameters. Unlike intervention-oriented trials, where a drug is compared to standard care or a placebo, a platform trial is disease centric, determining what therapy is optimal for a given indication or sub-population. Platform trials can also flexibly amend the control or "standard of care" group as the study progresses. For example, when a platform trial reveals the efficacy of a candidate therapeutic to be superior to existing "standard of care," said new candidate can be rolled out to benefit patients immediately and in turn become the new "standard of care" against which all new therapeutics are measured in the trial.

[underlined: Real-world data:] FDA defines real-world data as "data relating to patient health status and/or the delivery of health care routinely collected from a variety of sources. Examples of real-world data include data derived from electronic health records, medical claims data, data from product or disease registries, and data gathered from other sources (such as digital health technologies) that can inform on health status."

[underlined: Real-world evidence:] FDA defines real-world evidence as "the clinical evidence about the usage and potential benefits or risks of a medical product derived from analysis of [real-world data]." Real-world evidence can support clinical study design, inform clinical trial feasibility, and support regulatory risk-benefit assessments.